# PubMed: Advanced Search Builder

A tutorial describing how to use the Advanced Search Builder (http://www.ncbi.nlm.nih.gov/pubmed/advanced) to help refine your PubMed searches.

This video demonstrates how to use the PubMed Advanced Search Builder, a good way to refine your PubMed searches. I’ll start by clicking Advanced on the PubMed homepage and then selecting MeSH Terms from the All Fields menu. When I start to type my first term, hyperglycemia, the autocomplete feature offers possible MeSH Terms based on my entry. I’ll select hyperglycemia. Notice that terms entered in the builder are automatically added to the box above. I’ll add another term to my search by typing newborn on the second line. The default Boolean operator is AND; if desired, choose OR or NOT from the pull-down menu. Click ‘Add to history’ to display the result count for the search thus far; this is like using the Preview button on other advanced search pages. ‘Add to history’ also allows me to temporarily store this search for use in a subsequent searches. To permanently store the search, click on the search number in History. You can then choose, Save in My NCBI. If I click ‘Add’, my search is added to the search builder. I’ll continue to add terms by choosing MeSH Subheading in the next builder box. To see an alphabetical list of all terms in this search field, I’ll click ‘Show index list.’ Scroll until you find the correct term and then highlight it to add it to the search box. I’ll select drug therapy. To clean up the page a bit, I’ll click ‘Hide index list.’ If you are ready to retrieve your records, click ‘Search.’ If not, there are a few ways you can edit the search. You can continue to add terms, you can use the ‘-’ icon to remove a specific term, or use the Clear link to completey start over. If you want to manually change the Search Builder field, use Edit. Note that once you click edit, the Builder section disappears, because it can no longer control the search, however, your previous work is not lost. You can click Cancel to add the Builder back to the page, and History is still available. Give the Advanced Search Builder a try with your searches, and if you have comments or questions, use the link, “Support Center.”

This video is also available on YouTube. [image]http://youtu.be/dncRQ1cobdc