# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question 1 (Effectiveness)

We identified 9 systematic reviews that evaluated the effectiveness of yoga for one or more of our eligible conditions. These reviews in turn identified and summarized 23 unique RCTs. These RCTs were conducted primarily in North America and Asia. Typical enrollment was 25 to 50 adults, and the majority of subjects were white, female, and middle-aged. Interventions typically provided a total of 10 to 20 hours of yoga instruction and assessed outcomes across a wide range of follow-up periods. Yoga has been studied most extensively for low back pain and depressive disorders. The majority of the low back pain studies were judged by the systematic review authors to be at low risk of bias, while the majority of studies in patients with depressive disorder were judged to be at high risk of bias. Meta-analyses showed consistent short-term benefits of yoga for low back pain (SMD -0.48; 95% CI, -0.65 to -0.31; I2=0%) and more variable benefits for back-specific disability (SMD -0.59; 95% CI, -0.87 to -0.30; I2=59%). Compared with usual care, yoga improved short-term depressive symptoms (SMD -0.69; 95% CI, -0.99 to -0.39), but effects varied substantially across studies (I2=86%). For the other conditions, the lack of RCTs precluded estimates of treatment effects. Other outcomes such health-related quality of life were reported infrequently.

The conditions selected for this report are high impact—they are prevalent in Veterans,69,70 cause considerable functional impairment,71 and are associated with increased utilization of medical resources.72,73 Effective treatments are available for these conditions, but some patients do not respond adequately to first- or second-line treatment, and the availability of some established treatment options (eg, physical therapy or cognitive behavioral therapy) is limited or the cost is high. Furthermore, some patients may prefer alternatives to current treatment options. Understanding whether and how yoga may fit into the current treatment options is a worthwhile goal. As a first step, we surveyed current evidence, focusing on RCTs, and through this process, identified gaps in evidence. As described in the “Limitations” section below, there are important issues related to patient selection, trial reporting, short-term outcomes, and incomplete reporting of clinically important outcomes including effects on function and adverse effects.

### Key Question 2 (Adverse Effects)

We identified a single good-quality systematic review of adverse effects associated with yoga (for any clinical condition). This review identified 37 case reports or case-series of adverse effects, representing 76 individual adverse effects occurring in patients engaged in yoga. The headstand was associated most commonly with adverse outcomes, but most reports of adverse effects did not have clear descriptions of the postures involved. Musculoskeletal injuries, orbital involvement, and headache were the most common adverse effects. In the systematic reviews identified for clinical conditions of interest, only the studies of yoga for low back pain reported adverse effects.

## LIMITATIONS

### Limitations of Our Approach

We evaluated the published literature as reflected by English-language systematic reviews and recently published, large RCTs. There may be pertinent information from small RCTs or observational studies that were not included in published systematic reviews and did not meet our eligibility criteria. Although we verified selected data from the primary publications, we largely relied on the information provided in the eligible systematic reviews; we do not know if there were data abstractions or synthesis errors in one or more of the systematic reviews.

We included studies that used the term “yoga” to describe one or more interventions, but we may have missed studies that evaluated yoga as described or defined using a different term. We did not include studies of interventions that included components highly related to yoga, such as mindfulness-based stress reduction training. Another limitation is that yoga is typically practiced along with other interventions (eg, relaxation, exercise, dietary changes), but most of the studies included in this report attempted to evaluate the independent effect of yoga. Our search and eligibility criteria were designed to identify studies conducted in patients with clinical disorders or at least sufficient symptoms where individuals were at high risk for the disorder (eg, a positive depression screen). During our screening process for eligible studies, we identified studies that evaluated yoga for wellness or general health benefits in study samples that did not meet these eligibility criteria. Some of these studies measured the effects of yoga for symptoms of depression, anxiety, or sleep quality. Although not eligible for this review, studies of this nature could provide useful information on the effect of yoga on mood, sleep quality or global well-being in generally healthy individuals.

### Study Quality

We rated the systematic reviews for quality, but for the primary studies we relied on the quality ratings assigned by the authors of the systematic reviews. Based on the systematic reviewers' ratings of the primary studies, low back pain is the only condition where the preponderance of evidence comes from studies at low risk of bias. The quality of the evidence as reflected in both the primary studies and the systematic reviews is generally poor for all of the conditions except for low back pain.

### Heterogeneity

Individual studies included in systematic reviews for each condition of interest varied greatly in terms of the yoga styles studied, comparison groups used, duration and intensity of interventions, and other methodological aspects. The clinical populations were relatively similar across the primary studies of chronic low back pain, but the screening and diagnostic instruments used for the other conditions varied widely. The systematic reviews and primary studies reported limited information about the training of yoga instructors, the level of instruction provided to subjects, the amount of time subjects practiced yoga during the intervention periods, and other information necessary to evaluate the dosing of interventions. Given the limited reporting of this information, it is difficult to assess the variability across studies in this respect, but it is reasonable to assume that studies differed in terms of the training of yoga instructions and the nature and amount of practice performed by the subjects. Authors of several of the systematic reviews assessed included studies for heterogeneity, but those findings are limited because of the relatively small number of studies included in each systematic review. Overall, methodological and clinical heterogeneity was relatively high for all of the conditions of interest.

### Publication Bias

Assessment of possible publication bias was not reported by the authors of the systematic reviews, and we did not assess publication bias independently. Funnel plots and other formal assessments of publication bias are generally indicated only for meta-analyses that include 10 or more studies, but the largest meta-analysis reviewed in this report included only 8 studies of yoga for low back pain. Our search of ClinicalTrials.org identified 9 completed studies for which we did not identify a peer-reviewed publication, suggesting possible publication bias.

### Applicability of Findings to the VA Population

None of the primary studies that were eligible for inclusion in this report specifically involved Veteran populations. For the most part, the populations studied represent generally healthy, middle-aged adults, most of whom were women. The applicability of the effectiveness and safety findings for older populations or populations characterized by multiple comorbidities is limited. There is also limited applicability of the findings to the many conditions for which few or no studies were identified, such as acute (as opposed to chronic) low back pain, prevention of falls, general anxiety disorder, or insomnia.

## RESEARCH GAPS/FUTURE RESEARCH

In Table 11, we summarize key gaps in the literature and the types of studies that might address those gaps. If the VA or other organizations were to prioritize further research on yoga for these conditions, we recommend considering the study designs listed in the table, with careful attention paid to study design and reporting. For example, for low back pain and depression, where there are already RCTs, new or more in-depth evidence syntheses are not currently needed, but additional trials with active comparators may be helpful. For conditions examined by small or poor-quality trials (eg, depressive disorders), larger, more rigorous trials would be informative. Trials in certain subgroups, such as specific etiologies of back pain, could help target yoga to those who would benefit most. For conditions for which RCTs are lacking, pilot studies could be conducted to provide preliminary evidence of potential effectiveness (or lack thereof) of yoga as a therapeutic intervention. For all of the conditions for which yoga may be effective, longer-term, validated, patient-reported outcomes should be assessed, and stakeholders, including patients, should be involved in prioritizing outcomes to be measured for future studies. Feasibility and acceptability studies could also be conducted to identify potential barriers and facilitators for learning and practicing yoga among various Veteran populations. Finally, enhancement of the applicability of findings to Veterans could be achieved by including Veterans or patients with similar demographic characteristics to achieve better representation of men and older adults.

Table 11 Key Research Gaps by Clinical Condition

Condition | Gap | Surveillance for Updated SR | Recommended Study Designs | Outcomes
Low back pain | Acute back pain Subgroups (eg, young adults, or specific back pain etiologies) | Yes | Large RCTs, including pragmatic comparative effectiveness trials or type 2 hybrid implantation studies | Long-term functional status
Prevention of falls | No good-quality SR No RCTs | Yes^*^ | Pilot trials | Falls
Depressive disorders | Existing trials poor quality | Yes | Large RCTs, including pragmatic comparative effectiveness trials | Long-term functional status
Anxiety disorders (GAD/PD) | No good-quality SR 1 RCT | Yes^*^ | Pilot trials | Standardized outcome measures
PTSD | No good-quality SR Few RCTs | Yes^*^ | Systematic review when ongoing trials completed | Standardized outcome measures
Insomnia | No good-quality SR RCTs only in those at risk for sleep disorders | Yes^*^ | Pilot trials | Sleep quality

* No good-quality systematic review identified. If surveillance identifies new RCTs, a new, good-quality systematic review is recommended.

Abbreviations: GAD=generalized anxiety disorder; PD=panic disorder; PTSD=posttraumatic stress disorder; RCT(s)=randomized controlled trial(s); SR=systematic review

## CONCLUSIONS

We conclude that the evidence from good-quality systematic reviews suggests that yoga can improve functional outcomes in patients with nonspecific chronic low back pain. Existing evidence is less clear about the effectiveness and safety of yoga for the other conditions of interest. There is potential benefit for yoga in young to midlife adults with depressive disorders or elevated depressive symptoms. We found a limited amount of evidence (from nonrandomized studies and studies in samples related to the target population) that suggests that yoga may be beneficial for patients with symptoms of anxiety or insomnia. We found few trials that evaluated the effectiveness and safety of yoga for prevention of falls, PTSD, or insomnia. These findings and conclusions are generally consistent with those of a recent (2013) published review of systematic reviews of yoga for acute and chronic health conditions which concluded that yoga appears most effective for reducing symptoms in anxiety, depression, and pain.23 The authors of this review of reviews concluded, as we do, that the quality of existing systematic reviews is generally high, whereas the quality of the primary studies is generally low.