# RESULTS

In this section of the report, we report the results of the literature search, followed by a meta-synthesis describing the volume of studies across all conditions. We then describe the findings by condition, prioritizing findings from systematic reviews.

## LITERATURE FLOW

The flow of articles through the literature search and screening process is shown in Figure 1. A combined search of PubMed, the Cochrane Database of Systematic Reviews, and Embase on the 7 conditions of interest yielded 776 articles. By condition, there were 76 articles on low back pain, 48 on prevention of falls, 176 on depressive disorders, 226 on anxiety disorders (generalized anxiety disorder or panic disorder), 28 on PTSD, and 157 on insomnia. The AMED search on yoga in general (n=199), the search in PubMed on adverse effects (n=126), and a review of the bibliographies of key articles (n=11) provided an additional 336 articles, for a total of 1112 articles. After removing duplicates—articles identified for more than one condition or in more than one database (n=97)—the final dataset contained 1015 unique citations.

Figure 1 Literature Flow Chart

Abbreviations: AMED=Allied and Complementary Medicine Database; GAD=generalized anxiety disorder; PD=panic disorder; PTSD=posttraumatic stress disorder; RCT=randomized controlled trial; SR=systematic review

After applying inclusion and exclusion criteria at the title-and-abstract level, 105 full-text articles were retrieved. Of these, 95 were excluded, leaving 10 articles consisting of 9 systematic reviews and one recent “review of reviews” that was used to evaluate the completeness of our literature review. No additional eligible reviews were identified in this review of reviews.23 We did not identify any eligible RCTs (n≥100) that were not included in an eligible systematic review. The search of PROSPERO and the Cochrane Database of Systematic Reviews identified only one relevant systematic review protocol, registered in 2013, to address yoga for chronic low back pain.24 The search of ClinicalTrials.gov identified 15 studies which were either completed but unpublished (n=9) or ongoing (n=6). These are detailed in Appendix F.

## OVERVIEW OF RESULTS

We identified 9 systematic reviews that pertained to a Key Question (Table 1).25-33 Three of these focused on chronic low back pain; one focused on yoga for prevention of falls but did not identify any primary studies that reported falls as an outcome; 4 focused on mental illness (2 on depression and 2 on depressive disorders, anxiety disorders, and PTSD); one focused on insomnia but did not identify any primary studies that included patients with a clinical diagnosis of insomnia; and one focused on adverse effects. RCTs identified in the eligible systematic reviews included 10 RCTs representing 956 patients with chronic low back pain, 12 RCTs representing 619 patients with depressive disorders, and one RCT representing 11 patients with PTSD (Figure 2). The eligible systematic reviews did not include any RCTs of yoga for prevention of falls, generalized anxiety disorder, panic disorder, or insomnia. Good-quality systematic reviews were identified for low back pain, depressive disorders, and adverse effects. Generalized anxiety disorder, panic disorder, PTSD, and insomnia were reviewed in fair- to poor-quality systematic reviews. Detailed quality ratings for each systematic review are provided in Appendix G. There were no RCTs with n≥100 published since 2011 that met our criteria and had not been included in one of the eligible systematic reviews. We identified 10 RCTs with n<100 not captured by the included systematic reviews (Appendix H); 3 of these focused on low back pain,34-36 2 on prevention of falls,37,38 2 on major depressive disorder,39,40 one on generalized anxiety disorder,41 and 2 on PTSD.42,43

Table 1 Characteristics of Systematic Reviews Evaluating Yoga for All Eligible Conditions

Characteristic | Cramer 2013^30^ | Holtzman 2013^29^ | Posadzki 2011^31^ | Jeter, 2014^33^ | Cramer, 2013^25^ | Balasubramaniam, 2013^26^ | Cabral, 2011^27^ | da Silva, 2009^28^ | Cramer, 2013^32^
Condition(s) | Low back pain | Low back pain | Low back pain | Prevention of falls | Depressive disorders | Multiple mental illnesses; insomnia | Multiple mental illnesses | Mood and anxiety disorders | Adverse effects
Search date | January 2012 | November 2011 | March 2011 | June 2012 | January 2013 | June 2011 | Not reported | July 2008 | February 2013
Databases searched | PubMed Embase Cochrane Library CAMbase | CINAHL MEDLINE Global Health Cochrane Central Register of Controlled Trials Embase PsycINFO | PubMed Cochrane Central Register of Controlled Trials Clinical Trial Registry of Indian Council Embase CINAHL AMED PsycINFO | PubMed IndMED Web of Knowledge Embase EBSCO Science Direct Google Scholar | PubMed Scopus Cochrane Library PsycINFO IndMED Gray literature | MEDLINE Cochrane Central Register of Controlled Trials Embase PsycINFO | PubMed Cochrane Central Register of Controlled Trials Google Scholar EBSCO | PubMed PsycINFO | PubMed CAMbase IndMED Scopus Cases Database
Study designs included | RCTs | RCTs | RCTs | RCTs; nonrandomized studies | RCTs | RCTs | RCTs | RCTs; nonrandomized studies | Case reports; case series
Studies included
All disorders | 10 | 8 | 7 | 15 | 12 | 16 | 10 | 34 | 37
Relevant studies^*^ | 10 | 8 | 7 | 0 | 12 | 2 | 4 | 3 | 37
Meta-analysis performed? | Yes | Yes | No | No | Yes | No | Yes | No | No
Systematic review quality | Good | Good | Good | Fair | Good | Moderate | Low | Low | Good

* RCTs evaluating yoga for adults with low back pain, prevention of falls, depressive disorders, generalized anxiety disorder, panic disorder, PTSD, or adverse effects. The mental illnesses had to be diagnosed by a clinician, meet DSM or similar criteria, or score above a threshold on a validated screening instrument.

Abbreviations: DSM=Diagnostic and Statistical Manual of Mental Disorders; PTSD=posttraumatic stress disorder; RCTs=randomized controlled trials

Figure 2 RCTs Evaluating Yoga

Notes to Figure 2:

* Represents prevention of falls, GAD, PD, and insomnia (no RCTs identified for any of these conditions).

Number of RCTs/number of patients for the various other conditions represented were: 1/8 for PTSD; 10/956 for LBP; and 12/619 for depression.

Abbreviations: GAD=generalized anxiety disorder; LBP=low back pain; PD=panic disorder; PTSD=posttraumatic stress disorder; RCT(s)=randomized controlled trial(s)

Overall, the included reviews identified 23 unique RCTs evaluating yoga for one of our eligible conditions (Table 2). These RCTs were conducted in North America (n=12), Asia (n=8), and Europe (n=3). Typical enrollment was 25 to 50 patients. The median of the mean ages was 44 years (range 21.5 to 66.5). Median sex was 75% female (range 37% to 100%). Interventions typically provided 10 to 20 hours of yoga and assessed outcomes over a range of 3 days to 24 weeks, with a median of 8 weeks. Yoga was most commonly compared to attention controls (eg, education), usual care, or exercise. In 9 of the 10 RCTs for low back pain, the authors specified that certified or experienced teachers served as instructors, but this was the case for only 5 of the 12 RCTs of yoga for depression. A total of 15 studies reported the experience or certification of the yoga instructors.

Table 2 Summary of Primary RCTs for All Eligible Conditions

Characteristic | Low Back Pain | Prevention of Falls | Depressive Disorders | Anxiety Disorders | PTSD | Insomnia
Number of systematic reviews | 3 | 1 | 4^*^ | 2^*^ | 2^*^ | 1
Number of RCTs (number of patients) | 10 (956) | 0 (0) | 12 (639) | 0 (0) | 1 (11) | 0 (0)
Systematic review quality
Good | 3 | - | 1 | - | 0 | -
Moderate | 0 | - | 1 | - | 0 | -
Low | 0 | - | 2 | - | 1 | -
Meta-analysis performed? | Yes | No | Yes | Yes | No | No
Geographical location
North America | 6 | - | 5 | - | 1 | -
Europe | 2 | - | 1 | - | 0 | -
Asia | 2 | - | 6 | - | 0 | -
Other/NR | 0 | - | 0 | - | 0 | -
Sample size of RCTs
1-50 | 4 | - | 8 | - | 1 | -
51-100 | 3 | - | 4 | - | 0 | -
>100 | 3 | - | 0 | - | 0 | -
Yoga style
Iyengar | 3 | - | 1 | - | 0 | -
Hatha | 2 | - | 1 | - | 0 | -
Viniyoga | 2 | - | 0 | - | 0 | -
SKY | 3 | - | 2 | - | 0 | -
Other/NR | 0 | - | 8 | - | 1 | -
Treatment duration
<4 weeks | 2 | - | 3 | - | 0 | -
5-12 weeks | 6 | - | 8 | - | 0 | -
>12 weeks | 2 | - | 0 | - | 0 | -
NR | 0 | - | 1 | - | 1 | -

* We identified a total of 4 systematic reviews of yoga for mental illness; 2 of these reported findings for depressive disorders, anxiety disorders, and PTSD.

Abbreviations: NR=not reported; PTSD=posttraumatic stress disorder; RCTs=randomized controlled trials; SKY=Sudarshan Kriya Yoga

## KEY QUESTION 1 What are the extent, distribution, and methodological designs of intervention studies that evaluate yoga for the following conditions?

- Low back pain
- Prevention of falls
- Mental illness:
  ○ Depressive disorders
  ○ Anxiety disorders (generalized anxiety disorder and panic disorder)
  ○ Posttraumatic stress disorder (PTSD)
- Insomnia

### Yoga for Low Back Pain

We identified 3 eligible systematic reviews that evaluated yoga for low back pain (Table 3).29-31 All 3 included only RCTs, and all focused exclusively on chronic low back pain. Additional RCTs with n≥100 were not identified outside those included in the systematic reviews; 3 recent RCTs with n<100 were identified, but are not considered here because they did not meet eligibility criteria (Appendix H).34-36 Our search of ClinicalTrials.gov identified one small (n=10) completed but unpublished trial (NCT01963871) and one large (n=320) planned active but not recruiting clinical trial (NCT01343927; Appendix F).

Table 3 Characteristics of Systematic Reviews Evaluating Yoga for Low Back Pain

Characteristic | Cramer 2013^30^ | Holtzman 2013^29^ | Posadzki 2011^31^
Condition(s) | Chronic low back pain | Chronic low back pain | Chronic low back pain
Search date | January 2012 | November 2011 | March 2011
Databases searched | PubMed Embase Cochrane Library CAMbase | CINAHL MEDLINE Global Health Cochrane Central Register of Controlled Trials Embase PsycINFO | PubMed Cochrane Central Register of Controlled Trials Clinical Trial Registry of Indian Council Embase CINAHL AMED PsycINFO
Study designs included | RCTs | RCTs | RCTs
Studies included | 10 | 8 | 7
Meta-analysis performed? | Yes | Yes | No
Systematic review quality | Good | Good | Good

Abbreviation: RCTs=randomized controlled trials

We focus our discussion on the most recent, good-quality review by Cramer et al,30 which evaluated all of the RCTs included in the other 2 reviews (Appendix I). This review searched 5 computerized databases and the gray literature for eligible RCTs published through January 2012. The review included 10 RCTs that evaluated yoga compared with active or inactive controls in adult patients with a clinical diagnosis of low back pain of a nonspecific origin. Eligibility criteria allowed a range of symptom duration, pain intensity, and functional deficits. The review included trials of yoga interventions of any tradition, intensity, style, or duration. Other treatments (eg, medications) concurrent with yoga were allowed in all trials. Studies were included if they reported one of the following patient-centered outcomes: pain, back-specific disability, quality of life, generic disability (eg, activities of daily living, work absenteeism), and global improvement. Data on adverse effects were reported when available. When there were sufficient studies, the systematic review authors computed summary estimates of treatment effects using a random-effects meta-analysis with RevMan 5.1 software.44

Ten RCTs that randomized 956 patients with low back pain were included. Of these, 8 were included in meta-analyses; the other 2 were excluded due to poor quality. Detailed study characteristics for each study are presented in Appendix J and summarized in Table 4, below. Most trials enrolled midlife adults (median age 48.0), and all focused specifically on chronic low back pain. No study enrolled Veterans or active duty military. More women (median proportion 69.3%) than men were enrolled.

Table 4 Characteristics of RCTs Evaluating Yoga for Low Back Pain Included in Cramer et al30

Characteristic | Studies (n=10)
Condition
Low back pain <3 months | 1
Low back pain ≥3 months | 6
Low back pain ≥6 months | 1
Low back pain ≥3 months plus a physical functional deficit | 2
Population age
Adults | 10
Geographical region
North America | 6
Europe | 2
Asia | 2
Sample size
25-50 | 4
>50-100 | 3
>100 | 3
Yoga style
Iyengar | 3
Hatha | 2
Viniyoga | 2
Other | 3
Treatment duration
≤4 weeks | 2
5-12 weeks | 6
>12 weeks | 2
Treatment intensity
<10 hours | 1
10-20 hours | 9
Timing of outcome assessment^a^
≤3 months | 3
>3-6 months | 6
>6 months | 5

a Some studies assessed outcomes at multiple time points.

Abbreviation: RCTs=randomized controlled trials

Yoga was conducted by certified or experienced yoga teachers in 9 trials; the instructor's qualifications were not clearly reported in one trial. The median number of hours planned for the yoga intervention was 15 (range 3 to 72), delivered in programs that ranged from one to 24 weeks (median 11 weeks). Eight studies reported a co-intervention with yoga. Co-interventions consisted of usual or routine care (n=3), education (n=3), and lifestyle and diet changes (n=2). Most of the included studies used a 2-arm study design (n=8); 2 studies used a 3-arm design. In the 2-arm studies, yoga was compared with wait-list control (n=3) plus routine care or education; standard care (n=1); education (n=1); lifestyle change (n=1); or physical therapy and exercise (n=1). In both 3-arm studies, yoga was compared with exercise in one arm and an educational intervention in the other. Three RCTs used exercise as a comparator. A combination of short- and long-term outcomes were assessed at a median of 12 weeks (range one week to 6 months) for short-term outcomes (n=10) and at a median of 28 weeks (range 26 weeks to one year) for long-term outcomes. In 9 of the 10 RCTs, the authors specified that certified or experienced teachers served as instructors.

The systematic review authors judged 8 RCTs to be at low risk of bias, and 2 to be at high risk of bias. Compliance with the intervention was found to be unclear or unacceptable in 4 of the 10 studies. Statistical methods to assess publication bias were not used because there were too few studies in the final analyses.

Meta-analysis showed consistent evidence for short-term benefits of yoga on pain (n=6; SMD -0.48; 95% CI, -0.65 to -0.31; I2=0%). Long-term effects of yoga revealed evidence for reduction in pain (n=5; SMD -0.33; 95% CI, -0.59 to -0.07; I2=48%) and back-specific disability (n=5; SMD -0.35; 95% CI, 0.55 to -0.15; I2=20%). Yoga also improved short-term back-specific disability (n=8; SMD -0.59; 95% CI, -0.87 to -0.30), but with moderate heterogeneity in treatment effects (I2=59%). No short-term (n=4; SMD 0.41; 95% CI, -0.11 to 0.93) or long-term effect (n=2; SMD 0.18; 95% CI, -0.05 to 0.41) was found for health-related quality of life. Most adverse effects were mild to moderate. Severe adverse effects consisted of a herniated disk (n=1) and severe pain (n=1). One study reported dropouts due to respiratory tract infections (n=2). The authors concluded: “This systematic review found strong evidence for short-term effectiveness and moderate evidence for long-term effectiveness of yoga for chronic [low back pain] in the most important patient-centered outcomes. Given the low number of adverse events, yoga can be recommended as an additional therapy to patients who do not improve with education on self-care options.”

The review by Cramer et al included separate analyses for both short- and long-term effects of yoga in comparison to usual care, education, or exercise. Yoga showed short-term benefit for low back pain, back-specific disability, and health-related quality of life compared with education. For the other comparators, there was not a consistent pattern of benefit for pain, disability and health-related quality of life. Over the longer term, yoga was beneficial for low back pain compared with education. However, the subgroup analyses were conducted on small groups of studies, and testing for significance of these subgroups was not specified. These subgroup analyses should be considered exploratory, and the observed variability in treatment effects was not adequately explained.

The other 2 systematic reviews29,31 evaluated the same question and similar literature as Cramer et al, but did not add important additional information about the effect of yoga on chronic low back pain. The review by Holtzman et al29 was published in 2013 and included all but one45 of the studies included in Cramer et al. Similar results for short- and long-term pain and back-specific function were found in Holtzman et al compared with Cramer et al; however, the review by Holtzman et al did not assess short- or long-term effects of yoga on health-related quality of life among patients with chronic low back pain. The review by Holtzman et al concluded that “the results of the present study indicate that yoga may be an efficacious adjunctive treatment for chronic low back pain.” The quality of this review was fair because the study selection process was not adequately described. The review by Posadzki et al31 was published in 2011 and did not include a timeframe for the search strategy. Seven of the 10 studies from the review by Cramer et al are included in the review by Posadzki et al; the 3 studies not included were published in 2009,^46^ 2010,^47^ and 2011,^48^ and may not have been within this review's search timeframe. The review by Posadzki et al concluded that “the evidence that yoga alleviates chronic [low back pain] in the majority of studies is positive.” Two studies by Groessl49,50 conducted on Veterans were not included in these previous reviews and did not meet eligibility criteria for this review. Both of these studies were open-label pre-/post-intervention trials. One was conducted in the general VA population and the other specifically in women Veterans. The findings from both studies suggest that yoga may improve the health of Veterans,50 and that women may experience a greater effect from yoga than men.49

#### Summary of Findings for Low Back Pain

Although we rated the review by Cramer et al30 as good quality, there were some limitations. The subgroup analyses were conducted on small groups of studies—groups that fall below the recommended minimal threshold for these analyses.51 Decreased intervention compliance and dropout rate were found to be unclear or not acceptable in 4 out of 10 studies; however, no sensitivity analysis was conducted to determine if this might have had a significant influence on pooled study estimates.

Overall, we conclude that the evidence suggests potential benefit of yoga in midlife adults with chronic nonspecific low back pain for short- and long-term pain and back-specific disability, but the effects of yoga for short- and long-term health-related quality of life are uncertain. The effects of yoga for acute or subacute low back pain or for the prevention of low back pain are also uncertain, as we did not identify eligible systematic reviews or RCTs that evaluated yoga for these stages of low back pain. For chronic low back pain, yoga appears to be a reasonable treatment option; however, given the multidimensional nature of chronic low back pain, yoga as a monotherapy may not be sufficient. Cognitive behavioral therapy has good evidence in the treatment of chronic low back pain and may be an interesting comparator or add-on therapy. There were few studies addressing long-term outcomes; therefore larger, good-quality RCTs with longer term outcomes that include functional status and health-related quality of life should be considered. Without additional studies, further systematic reviews are not needed.

### Yoga for Prevention of Falls

Our literature search identified one eligible systematic review of yoga for the prevention of falls. Jeter et al33 examined yoga for balance in a healthy population. This review, which searched 7 computerized databases and the gray literature for eligible trials published before August 2014, included 15 studies involving 687 subjects with an age range of 10 to 93 years. Five studies were RCTs, 4 were quasi-experimental, 2 were cross-sectional, and 4 were single-group designs. All but one of the included studies had an n<100, and none specifically studied a Veteran population. Although search terms included falls prevention, this review focused on use of yoga in a healthy population, whereas the area of interest for the purpose of our report is on patients who have had falls or who are at high risk of falls, thereby limiting the applicability of these results to our area of interest. The studies included in this systematic review used a variety of measures of balance as a surrogate measure for risk of falls. An outcome measure of frequency of falls would be preferred to surrogate measures of balance.

Given the lack of studies directly applicable to the population of interest, further investigation with larger, good-quality RCTs focused on patients who have had falls, or who are at high risk of falls, would be needed to address the efficacy of yoga for prevention of falls. We identified one RCT with n<100 of yoga for falls prevention;38 another appeared to be eligible based on review of the abstract,37 although we were unable to confirm eligibility, as the full manuscript was not available (Appendix H). Our search of ClinicalTrials.gov identified one small (n=40) completed but unpublished trial (NCT01806922) and no ongoing trials (Appendix F).

### Yoga for Mental Illness

We discuss the following conditions in this section: depressive disorders, anxiety disorders (generalized anxiety disorder and panic disorder), and PTSD.

#### Yoga for Depressive Disorders

We identified 4 systematic reviews that evaluated yoga for depressive disorders (Table 5).25-28 Three of these25-27 evaluated RCTs only, and the fourth28 included both RCTs and nonrandomized studies.25 Our independent search did not identify any additional RCTs with n≥100; 2 published39,40 (Appendix H) and 2 completed but unpublished RCTs (NCT01210651; NCT00482482) with n<100 (Appendix F) were identified. In addition, one ongoing trial with a planned enrollment of 150 patients was identified from ClinicalTrials.gov (NCT01384916; Appendix F).

Table 5 Characteristics of Systematic Reviews Evaluating Yoga for Depressive Disorders

Characteristic | Cramer, 2013^25^ | Balasubramaniam, 2013^26^ | Cabral, 2011^27^ | da Silva, 2009^28^
Condition(s) | Depressive disorders | Multiple mental illnesses | Multiple mental illnesses | Mood and anxiety disorders
Search date | January 2013 | June 2011 | Not reported | July 2008
Databases searched | PubMed Scopus Cochrane Library PsycINFO IndMED Gray literature | MEDLINE Cochrane Central Register of Controlled Trials Embase PsycINFO | PubMed Cochrane Central Register of Controlled Trials Google Scholar EBSCO | PubMed PsycINFO
Study designs included | RCTs | RCTs | RCTs | RCTs and nonrandomized studies
Studies included
All disorders | 12 | 16 | 10 | 34
Depressive disorders | 12 | 4 | 5 | 16
Meta-analysis performed? | Yes | No | Yes | No
Systematic review quality | Good | Moderate | Low | Low

Abbreviations: RCTs=randomized controlled trials

We focus our discussion on the most recent, good-quality review by Cramer et al,25 which included all of the RCTs identified in the 4 systematic reviews (Appendix K). The Cramer review searched 5 computerized databases and the gray literature for eligible RCTs published through January 17, 2013. Eligible studies included RCTs that evaluated yoga compared with active or inactive controls in adult patients with depressive disorders meeting DSM-IV or ICD-10 criteria, or with elevated levels of depressive symptoms as measured by a validated questionnaire. The review included RCTs of any duration and yoga interventions of any intensity or style. Mindfulness-based stress reduction or mindfulness-based cognitive therapy interventions—techniques that are related to some forms of yoga—were excluded. Outcomes considered were depression symptom severity, remission rates, anxiety symptoms, health-related quality of life, and adverse effects. When there were sufficient studies, summary treatment effects were estimated using a fixed-effect meta-analysis.

The review included 12 trials that randomized 619 patients with depression. Of these trials, 9 were included in meta-analyses; the other 3 were excluded due to differences in quality. Detailed study characteristics for each study are presented in Appendix L and summarized in Table 6, below. Most trials enrolled young to midlife adults (median age 33.7) who met the criterion standard for a depressive disorder. No study enrolled Veterans or active duty military. Substantially more women (median proportion 76.5%) than men were enrolled.

Table 6 Characteristics of RCTs Evaluating Yoga for Depressive Disorders Included in Cramer et al25

Characteristic | Studies (n=12)
Condition
Major depressive disorder or dysthymia | 6
Elevated depressive symptoms | 6
Population age
Adults | 11
Older adults (mean age >65) | 1
Geographical location
North America | 5
Europe | 1
Asia | 6
Sample size
25–50 | 8
>50 | 4
Yoga classification
Complex (eg, Ashtanga or Hatha yoga) | 3
Exercise-based (eg, Bikram or Power yoga) | 4
Not physical (eg, Pranayama only or Restorative yoga) | 5
Treatment duration
≤4 weeks | 3
5–12 weeks | 8
NR | 1
Treatment intensity
<10 hours | 3
10–20 hours | 6
NR | 3
Timing of outcome assessment
≤4 weeks | 4
5–12 weeks | 6
>12 weeks | 1
NR | 1

Abbreviations: NR=not reported; RCTs=randomized controlled trials

Yoga interventions were classified as nonphysical (no postures), exercise-based (postures only), or complex (postures plus meditation or breathing or both). Yoga was conducted by certified yoga teachers (n=5) or clinical psychologists (n=1); the remaining studies did not report the instructors' qualifications. The median number of hours planned for the yoga intervention was 11 (range 4 to 18), delivered in programs that ranged from 3 days to 12 weeks (median 8 weeks). Antidepressant co-medication was allowed in 3 studies, any co-intervention was allowed in 1 study, no co-interventions in 6 studies, and co-interventions were not reported in 2 studies. Yoga was compared with no treatment, standard care, or an unspecified control in 6 studies; with relaxation in 4 studies; and with aerobic exercise in 2 studies. One study compared yoga with an active comparator: a tricyclic antidepressant medication or electroconvulsive therapy. Outcomes were assessed at a median of 10 weeks (range 3 days to 9 months).

The systematic review authors judged 3 RCTs to be at low risk of bias and 9 to be at high risk of bias. Statistical methods to assess publication bias were not used because there were too few studies. The review did not include a search of clinical trial registries to look for completed but unpublished trials.

Compared with usual care, yoga improved short-term depressive symptoms (n=5; SMD -0.69; 95% CI, -0.99 to -0.39), but effects varied substantially across studies (I2=86%). Yoga was also more effective than relaxation (n=3; SMD -0.59; 95% CI, -1.03 to -0.22; I2=0%) and aerobic exercise (n=2; SMD -0.59; 95% CI, -0.99 to -0.18) for this outcome. Remission rates were reported infrequently. Short-term remission with yoga did not differ from electroconvulsive therapy in one study but was higher with yoga than with usual care and relaxation in one study each. One study found higher longer-term remission rates with yoga compared with usual care but no difference compared with group therapy. Only one study reported effects on health-related quality of life and found that patients assigned to the yoga group were more likely to have a 50% improvement than patients assigned to relaxation control. Although adverse effects were a prespecified outcome for the review, no results were reported for this outcome. The authors of this systematic review concluded: “Despite methodological drawbacks of the included studies, yoga could be considered an ancillary treatment option for patients with depressive disorders and individuals with elevated levels of depression.”

To explore the observed variability in short-term effects on depression severity, subgroup analyses were conducted in studies of patients with DSM-IV disorders versus those with elevated depressive symptoms and by category of yoga (ie, complex, exercise-based, not physical). These analyses suggested that yoga may be more effective in individuals with elevated depressive symptoms not meeting criteria for a DSM-IV disorder, but analyses were limited by very small subgroups (n≤3) and should be considered hypothesis-generating. Another subgroup analysis was conducted by control group (usual care, relaxation, or aerobic exercise); the benefits of yoga were similar across the different control groups. The authors concluded: “Despite methodological drawbacks of the included studies, yoga could be considered an ancillary treatment option for patients with depressive disorders and individuals with elevated levels of depression.”

The other 3 eligible systematic reviews evaluated a broader set of mental illnesses but did not add important information about depressive disorders. All had search dates that substantially preceded the January 2013 search in Cramer et al.25 The review by Cabral et al27 included only 2 of 12 RCTs evaluated in the Cramer review. Three other trials included by Cabral et al − 2 nonrandomized52,53 and one in patients with alcohol dependence54 – were appropriately excluded from the Cramer review. The review by da Silva et al28 included 7 of the 12 RCTs evaluated by Cramer and additional nonrandomized studies (Appendix M). Most of the nonrandomized studies were small, short-term, open trials. The review by Balasubramaniam et al26 included only one of the RCTs identified by Cramer and colleagues and no unique studies compared with the other reviews. A table showing the unique studies included in each review is in Appendix K.

##### Summary of Findings for Depressive Disorders

Although we rated the review by Cramer et al25 as good quality, there were some limitations. Meta-analyses were conducted separately for yoga versus usual care and versus relaxation controls. Depending on the usual care treatments given (not described in the report), it may have been reasonable to group these controls together. As with the review by Cramer et al for back pain,30 subgroup analyses for depression were conducted on small groups of studies. Finally, although adverse effects were a prespecified outcome, no data on this outcome were presented. Given the limitations of the analyses, the high risk of bias in 9 of the 12 primary trials, the unexplained variability in treatment effects, and an incomplete array of short-term, patient-important outcomes, we reached a different conclusion than the review authors. We think these studies suggest potential benefit for yoga in young to midlife adults with depression, but our confidence in the treatment effect is low. Without new trials, further systematic reviews are not currently needed, but a literature scan in 3 to 5 years could be done to re-evaluate the need for an updated systematic review. Larger, higher quality RCTs with longer term outcomes that include depression severity, functional status, and adverse effects would be needed to more fully evaluate the effects of yoga. Ideally, these studies should include Veterans or patients with demographic and clinical characteristics comparable to the Veteran population. Given that yoga may require a time commitment similar to evidence-based short-term psychotherapies such as cognitive-behavioral or problem-solving therapy, careful consideration should be given to the appropriate comparator. For subsyndromal depression, yoga may be a reasonable option as monotherapy, and comparators could include attention control or active treatments. For major depressive disorder, yoga could be an alternative to other active treatments or used as an add-on therapy for patients treated with antidepressants.

#### Yoga for Anxiety Disorders (Generalized Anxiety Disorder and Panic Disorder)

We identified 2 systematic reviews that met our selection criteria for anxiety disorders (Table 7).27,28 These reviews also evaluated yoga for depressive disorders and PTSD; the methodological approach for these reviews was described in the earlier section on depressive disorders. Both systematic reviews were rated poor quality and included studies that enrolled patients with anxiety symptoms outside the generalized anxiety disorder or panic disorder spectrum. For these reasons, we provide only a brief description of each systematic review, accompanied by a description of the primary studies relevant to generalized anxiety disorder or panic disorder. Our independent search identified one additional RCT with n<10041 (Appendix H).

Table 7 Characteristics of Systematic Reviews Evaluating Yoga for Anxiety Disorders

Characteristic | da Silva, 2009^28^ | Cabral, 2011^27^
Conditions | Mood and anxiety disorders | Multiple mental illnesses
Search date | July 2008 | NR
Databases searched | PubMed PsycINFO | PubMed Cochrane Central Register of Controlled Trials Google Scholar EBSCO
Study designs included | RCTs and nonrandomized studies | RCTs
Studies included
All disorders | 34 | 10
Anxiety disorders | 8 | 4
Meta-analysis performed? | No | Yes
Systematic review quality | Poor | Poor

Abbreviations: RCTs=randomized controlled trials

The poor-quality review by da Silva et al included studies of any design that evaluated yoga of any style or practice element for mood disorders, PTSD, and anxiety disorders. Yoga styles included Hatha yoga, SKY, Iyengar, Vinyasa, and Vivekananda. Active and inactive comparators were included. Meta-analysis was not performed, and qualitative analysis of studies was limited to brief descriptions of findings. Practice elements of the intervention, as well as session number, duration, and frequency, were not reported.

Of the 8 included studies that evaluated yoga for an anxiety disorder, only 4 were relevant to our study question. The other 4 studies addressed yoga as a treatment for “snake phobia,” yoga as a treatment for “psychoneurosis” (a psychoanalytic term not currently recognized in the DSM-IV), and yoga as a mindfulness-based stress reduction intervention. We focus on the 4 studies evaluating yoga for patients with symptoms in the generalized anxiety disorder or anxiety neurosis categories (Table 8).

Table 8 Characteristics of Nonrandomized Studies Evaluating Yoga for Anxiety Disorders Included in da Silva et al28

Characteristic | Studies (n=4)
Condition
Anxiety neurosis | 3
General anxiety disorder | 1
Population age
Adults | 4
Geographical location
North America | 2
Asia (India) | 2
Sample size
<25 | 2
50–100 | 2
Yoga classification
Physical postures | 1
Breathing exercise (Pranayama) | 1
Meditation | 1
Unspecified | 1
Treatment duration
3 months | 3
6–8 months | 1
Treatment intensity
25-50 hours | 2
>50 hours | 1
NR | 1
Timing of outcome assessment
3 months | 2
12 months | 1
NR | 1

Abbreviation: NR=not reported

Of these 4 studies (n=174 participants), 3 enrolled individuals with “anxiety neurosis,”55-57 while a small case series58 enrolled patients with generalized anxiety disorder. All studies enrolled both sexes, and the overall age range of participants was 18 to 47 years of age. Study designs included 2 nonrandomized comparative studies,55,56 a single-arm trial,57 and a case series.58 Comparators were placebo capsule55 and drug therapy with diazepam.56 Yoga interventions were delivered for 3 months to 6-8 months, offering 28 to 112 hours of yoga, although 2 studies emphasized self-directed practice. The yoga interventions examined were heterogeneous, including 2 breathing exercises,55, an Asana series,56 and transcendental meditation.57 Outcomes measured include anxiety severity measures,55-57 physiologic measures,55 psychiatric assessment of symptoms,56 and self-reported medical symptoms.56 All of the studies demonstrated some positive effects of yoga for anxiety symptoms, but statistically significant differences were not always sustained, and high attrition represented a significant study limitation. The review authors concluded that the evidence for the benefit of yoga is still preliminary for anxiety disorders.

Cabral et al27 included RCTs on yoga for multiple conditions: depression, anxiety-related disorders, PTSD, bipolar disorder, and schizophrenia. Yoga interventions of any style and any practice element were included, and comparators considered were unspecified “controls.” Ten studies (343 participants) for various psychiatric disorders were included. Based on summary tables in the systematic review, supplemented by our review of the primary studies, 4 of the 10 included studies52,53,59,60 evaluated yoga for anxiety, including 3 that evaluated yoga for both depression and anxiety.52,53,59 None of the studies enrolled patients with generalized anxiety disorder or panic disorder, and none used a validated instrument for anxiety symptoms to identify eligible patients. Thus, these studies do not address the conditions of interest in this report, but rather address less defined emotional distress and anxiety symptoms.

##### Summary of Findings for Anxiety Disorders

Our analysis identified 2 poor-quality systematic reviews that included studies evaluating various yoga practices for anxiety disorders.27,28 Our search identified one additional RCT (total n=12) published in 2013.^41^ Both reviews included studies that did not employ diagnostic criteria for anxiety as eligibility criteria, or used diagnoses tangentially related to the anxiety disorders of interest (eg, snake phobia, psychoneurosis). In the case of Cabral et al,27 none of the included studies met our criteria for inclusion as primary studies. The remaining studies from da Silva et al28 were nonrandomized studies or case series. There was a relatively high degree of heterogeneity in sample size, type of yoga practice employed, intervention intensity, and outcome measures related to anxiety among these studies. The studies did illustrate improvement in anxiety scores for those receiving a yoga-related intervention, although those improvements were not always sustained. There were numerous limitations in the primary studies, including high attrition rate, limited detail about intervention intensity (participant fidelity to practices), switching interventional approach with initial negative findings, subjective analysis of symptom severity, lack of control group, and lack of randomized control.

We agree with the assessment by da Silva et al28 that the evidence in support of potential effectiveness of yoga for anxiety disorders is preliminary. The evidence suggests that yogic exercises, including meditation, breathing, and postures, may have a positive, short-term effect on symptoms and severity of anxiety in those diagnosed with an anxiety disorder. We did not find sufficient studies to support an updated systematic review. Notably, RCTs that address yoga interventions for populations with generalized anxiety disorder or panic disorder were found to be lacking in our review. Existing studies might, however, serve as pilot studies to inform future RCTs that report intervention duration and intensity and employ well-validated outcomes measures. Our search of ClinicalTrials.gov identified one large (n=230) ongoing 3-arm RCT comparing yoga to mindfulness-based stress reduction and cognitive-behavioral therapy in patients with generalized anxiety disorder (NCT01912287; Appendix F).

#### Yoga for PTSD

We identified 2 eligible systematic reviews that evaluated yoga for treatment of PTSD or PTSD symptoms (Table 9).27,28 These reviews also evaluated yoga for depressive disorders; the methodological approach for these reviews was described in the earlier section on depressive disorders. Collectively, the 2 reviews identified a small RCT involving 8 PTSD patients61 and 2 nonrandomized studies involving a combined total of 22 PTSD patients.62,63 The small RCT did not report between-group treatment effects, and neither review drew conclusions specific to the efficacy of yoga for PTSD. Our independent search identified 2 additional RCTs conducted in the United States and evaluating yoga in women with PTSD, but both trials enrolled fewer than 100 subjects.42,43

Table 9 Characteristics of RCTs and Nonrandomized Studies Evaluating Yoga for PTSD

Characteristic | RCTs (n=1) | Nonrandomized Studies (n = 2)
Condition
PTSD | 1 | 2
Population age
Adults | 1 | 1
Older adults (mean age >65) | 0 | 0
NR | 0 | 1
Geographical location
North America | 0 | 0
Europe | 0 | 0
Asia | 0 | 0
Australia | 0 | 1
NR | 1 | 1
Sample size
<25 | 1 | 2
25–50 | 0 | 0
>50 | 0 | 0
Yoga classification
Complex | 0 | 1
Exercise-based | 1 | 1
Not physical | 0 | 0
Treatment duration
≤4 weeks | 0 | 0
5–12 weeks | 0 | 1
NR | 1 | 1
Treatment intensity
<10 hours | 0 | 1
10–20 hours | 1 | 0
NR | 0 | 1
Timing of outcome assessment
≤4 weeks | 0 | 0
5–12 weeks | 0 | 0
>12 weeks | 0 | 1
NR | 1 | 1

Abbreviations: NR=not reported; PTSD=posttraumatic stress disorder; RCTs=randomized controlled trials

##### Summary of Findings for Posttraumatic Stress Disorder

Both systematic reviews we identified27,28 were of poor quality, and the limited number of studies using different study designs, interventions, and outcomes were not amenable to meaningful meta-analysis. Neither review drew any summary conclusions about the efficacy of yoga for PTSD. We identified 2 additional RCTs published in 2014 that enrolled 3843 and 6442 women, respectively.

The limited number of studies with relatively few patients precludes any definitive conclusions regarding the potential benefit of yoga for PTSD or PTSD symptoms. Further research with well-conducted RCTs would be needed to evaluate the efficacy of this intervention. Our search of ClinicalTrials.gov identified one small (n=103) completed but unpublished trial (NCT00962403) and 3 trials (n=30 to 200) that have not yet begun recruitment (NCT01521442; NCT01512303; NCT01957371; Appendix F). An updated systematic review that included the 3 published trials together with 4 trials identified in ClinicalTrials.gov may be warranted once these studies are completed.

### Yoga for Insomnia

We identified one eligible fair-quality systematic review that included search terms for insomnia.26 This review did not find any primary studies that had a clinical diagnosis of insomnia as a subject eligibility criterion. It included one cluster RCT and 2 patient-level RCTs that evaluated yoga for individuals at increased risk for insomnia, many of whom had sleep complaints. The review searched 4 computerized databases (MEDLINE, Cochrane Central Register of Controlled Trials, Embase, and PsycINFO) for eligible RCTs published through June 2011 and included 3 trials that randomized 236 patients at high risk for sleep complaints. All 3 RCTs were judged to be of poor quality by the systematic review authors (evidence level 2 according to Oxford Center for Evidence-based Medicine). Study characteristics are summarized in Table 10, below. The trials enrolled midlife patients with cancer (139 participants) or older adults (median age 69 years) living in a nursing home (69 participants) or in the community (139 participants). No study enrolled Veterans or active duty military. The review did not describe detailed patient characteristics. Meta-analysis on sleep complaints was not performed due to the small number and high heterogeneity of the studies. Statistical methods to assess publication bias were not used because there were too few studies. There was no other assessment for publication bias.

Table 10 Characteristics of RCTs Evaluating Yoga for Insomnia or Sleep Complaints Included in Balasubramaniam et al26

Characteristic | Studies (n=3)
Condition
Diagnosis of insomnia | 0
Sleep complaints | 3
Population age
Adults (18-64) | 1
Older adults (age >60) | 2
Geographical location
North America | 1
Asia | 2
Sample size
25–50 | 1
50-100 | 1
>100 | 1
Yoga classification
Postures, breathing, and meditation | 3
Postures only | 0
Breathing or meditation only | 0
Treatment duration
≤8 weeks | 1
24 weeks | 2
Treatment intensity
<10 hours | 1
50–100 hours | 1
>100 hours | 1
Timing of outcome assessment^a^
≤8 weeks | 1
5–12 weeks | 1
>12 weeks | 2

a Some studies assessed outcomes at multiple time points.

Abbreviation: RCTs=randomized controlled trials

The review reported improved sleep with yoga in all RCTs examined. Significant improvements in total Pittsburgh Sleep Quality Index (PSQI) score and the subscales on sleep quality and latency were reported in 2 RCTs. Significant improvement in sleep duration and daytime disturbance were also observed in at least one RCT. The third showed improved within-group changes for sleep quality, latency, and duration but few changes between yoga and the control group. No adverse effects were reported. The review authors concluded: “Based on our assessment of the available literature according to the RAND/UCLA Appropriateness method, Grade C Evidence supporting a potential benefit for yoga exists for sleep complaints.” Grade C evidence was defined as low-grade data without the volume to recommend more highly and subject to revision with further studies. Our search of ClinicalTrials.gov identified 4 small (n=20, 40, 48, 50) completed but unpublished trials (NCT00033865; NCT01073423; NCT00994279; NCT01556074; Appendix F).

#### Summary of Findings for Insomnia

Our literature review identified only one fair-quality systematic review that used search terms for insomnia.26 It included 3 RCTs of yoga for sleep complaints in a variety of different patient populations. Interventions that included all 3 major elements of yoga practice regardless of style appear to have a positive effect on mild deficits in sleep quality, latency, and duration in patients at high risk for insomnia. Although the literature to date is inconclusive, these studies suggest that yoga may improve sleep quality and may be a reasonable intervention to test in individuals with insomnia. Larger, higher quality RCTs with active comparators and longer term outcomes enrolling individuals with insomnia would be needed to address this question.

## KEY QUESTION 2 What are the extent, distribution, and methodological designs of studies that assess the adverse effects of yoga?

We identified a single good-quality systematic review that specifically addressed adverse effects associated with yoga.32 This review included case reports and case series reporting adverse effects experienced by individuals engaged in yoga practices or postures, or practices with sufficient descriptions for the review authors to conclude that they were yoga. Reports included individuals with and without pre-existing medical conditions prior to beginning yoga. The authors searched MEDLINE/PubMed, CAMbase, IndMED, Scopus, and the Cases Database, all from inception through February 15, 2013; they identified 35 case reports and 2 case series, representing 76 individual adverse effects. Most of the reports (20 of 37) came from North America, while a quarter (9 of 37) were from Asian countries. The age range for included individuals was 14 to 87 years and 67% were women. Nine adverse effects were exacerbations of established medical conditions, one case occurred in someone with congenital connective tissue hyperelasticity, and 66 people had no reported baseline disorders or abnormalities. Six cases occurred with meditation or breathing alone (Siddha yoga, Pranayama, or breathing), while 7 involved more exercise-based techniques (Hatha, Vinyasa, or Bikram yoga); most reports did not specify the type of yoga being performed. The headstand (Sirsasana) was associated most commonly with adverse outcomes (10 cases), and 3 reports involved the shoulder stand, but most reports of adverse effects did not have clear descriptions of the postures involved. Musculoskeletal injuries were reported in 27 cases, while orbital involvement (9 cases, including new and worsening glaucoma and optic vascular events) and headache (7 cases) were the next most common types of effects. Notably, 7 of the adverse effects involving the eye and 2 of 3 reports concerning the posterior cerebrovascular system occurred during inversion poses (head or shoulder stand). In conclusion, the authors did not find evidence to support discontinuation of yoga by healthy people, but they warned beginner practitioners against headstand, lotus position, and advanced breathing techniques initially. In people with a history of glaucoma, they advised avoiding any inversion posture, and for those with baseline musculoskeletal disorders, they cautioned against “forceful or competitive yoga forms.”

In the systematic reviews we identified for clinical conditions of interest for this report (low back pain, prevention of falls, depressive disorders, anxiety disorders, PTSD, and insomnia), only the studies of yoga for low back pain reported adverse effects. In the review of low back pain by Cramer et al,30 3 studies reported 26 adverse effects among 248 included participants.48,64,65 Most adverse effects were mild to moderate, while 3 were severe. Severe adverse effects consisted of a worsening of back pain,64 a new diagnosis of herniated disc,66 and 2 subjects discontinuing the study due to respiratory tract infections.67,68 With most of the systematic reviews, it is unclear if adverse effects were truly not detected, or if this outcome was not addressed by the original study protocols and thus not captured. Given the small sample sizes of most RCTs included in the systematic reviews, it is possible that infrequent adverse effects may have been missed.