# REFERENCES

1 Stiles M. Yoga Sutras of Patanjali. San Francisco. Red Wheel, Weisner LLC. 2002.
2 Satyananda Saraswati S. Four Chapters on Freedom: Commentary on the Yoga Sutras of Patanjali. New Delhi. Yoga Publications Trust. 2005. 1st edition 1976.
3 Sturgess S. The Yoga Book: A Practical and Spiritual Guide to Self-Realization. London. Watkins Publishing. 2002.
4 Muktibodhananda S. Hatha Yoga Pradipika. New Delhi. Yoga Publications Trust. 2006. 1st edition 1985.
5 Broad WJ. The Science of Yoga: The Risks and the Rewards. New York. Simon and Schuster. 2012.
6 Zope SA, Zope RA. Sudarshan kriya yoga: breathing for health. Int J Yoga. 2013;6(1):4-10. [pmid: 23440614].
7 Newberg AB, Wintering N, Khalsa DS, Roggenkamp H, Waldman MR. Meditation effects on cognitive function and cerebral blood flow in subjects with memory loss: a preliminary study. J Alzheimers Dis. 2010;20(2):517-526. [pmid: 20164557].
8 Parker S, Bharati SV, Fernandez M. Defining yoga-nidra: traditional accounts, physiological research, and future directions. Int J Yoga Therap. 2013;23(1):11-16.
9 Arksey H. Scoping the field: services for carers of people with mental health problems. Health Soc Care Community. 2003;11(4):335-344. [pmid: 14629205].
10 Bragge P, Clavisi O, Turner T, Tavender E, Collie A, Gruen RL. The Global Evidence Mapping Initiative: scoping research in broad topic areas. BMC Med Res Methodol. 2011;11:92. [pmid: 21682870].
11 Ryan RE, Kaufman CA, Hill SJ. Building blocks for meta-synthesis: data integration tables for summarising, mapping, and synthesising evidence on interventions for communicating with health consumers. BMC Med Res Methodol. 2009;9:16. [pmid: 19261177].
12 Becker LA, Oxman AD. Chapter 22: Overviews of reviews. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.0.1 [updated September 2008]. The Cochrane Collaboration. 2008. http://www.cochrane-handbook.org. June 20, 2014.
13 Ioannidis JP. Integration of evidence from multiple meta-analyses: a primer on umbrella reviews, treatment networks and multiple treatments meta-analyses. CMAJ. 2009;181(8):488-493. [pmid: 19654195].
14 Shekelle PG, Ortiz E, Rhodes S, et al. Validity of the Agency for Healthcare Research and Quality clinical practice guidelines: how quickly do guidelines become outdated?. JAMA. 2001;286(12):1461-1467. [pmid: 11572738].
15 Moher D, Tsertsvadze A, Tricco AC, et al. A systematic review identified few methods and strategies describing when and how to update systematic reviews. J Clin Epidemiol. 2007;60(11):1095-1104. [pmid: 17938050].
16 Shojania KG, Sampson M, Ansari MT, Ji J, Doucette S, Moher D. How quickly do systematic reviews go out of date? A survival analysis. Ann Intern Med. 2007;147(4):224-233. [pmid: 17638714].
17 Moher D, Cook DJ, Eastwood S, Olkin I, Rennie D, Stroup DF. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].
18 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
19 Cohen JA. Statistical Power Analysis for the Behavioral Sciences. 2nd edition. Hillsdale, NJ. Erlbaum Associates. 1988.
20 Deeks JJ, Higgins JPT, Altman DG, editors. Chapter 9: Analysing data and undertaking meta-analyses. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.0.1 [updated September 2008]. The Cochrane Collaboration. 2008. http://www.cochrane-handbook.org. June 20, 2014.
21 Moher D, Tsertsvadze A, Tricco AC, et al. When and how to update systematic reviews. Cochrane Database Syst Rev. 2008;(1). MR000023.
22 Shojania KG, Sampson M, Ansari MT, et al. Updating Systematic Reviews. Rockville (MD). Agency for Healthcare Research and Quality (US). 2007. Sep. (Technical Reviews, No. 16). http://www.ncbi.nlm.nih.gov/books/NBK44099/. June 20, 2014.
23 McCall MC, Ward A, Roberts NW, Heneghan C. Overview of systematic reviews: yoga as a therapeutic intervention for adults with acute and chronic health conditions. Evid Based Complement Alternat Med. 2013;2013. Article Number: 945895.
24 Wieland LS, Skoetz N, Manheimer E, Pilkington K, Vempati R, Berman BM. Yoga treatment for chronic non-specific low-back pain (Protocol). Cochrane Database of Systematic Reviews. 2013;(7). Art. No.: CD010671. [doi: 10.1002/14651858.CD010671].
25 Cramer H, Lauche R, Langhorst J, Dobos G. Yoga for depression: a systematic review and meta-analysis. Depress Anxiety. 2013;30(11):1068-1083. [pmid: 23922209].
26 Balasubramaniam M, Telles S, Doraiswamy PM. Yoga on our minds: a systematic review of yoga for neuropsychiatric disorders. Front Psychiatry. 2013;3:117. [pmid: 23355825].
27 Cabral P, Meyer HB, Ames D. Effectiveness of yoga therapy as a complementary treatment for major psychiatric disorders: a meta-analysis. Prim Care Companion CNS Disord. 2011;13(4).
28 da Silva TL, Ravindran LN, Ravindran AV. Yoga in the treatment of mood and anxiety disorders: a review. Asian J Psychiatr. 2009;2(1):6-16. [pmid: 23051013].
29 Holtzman S, Beggs RT. Yoga for chronic low back pain: a meta-analysis of randomized controlled trials. Pain Res Manag. 2013;18(5):267-272. [pmid: 23894731].
30 Cramer H, Lauche R, Haller H, Dobos G. A systematic review and meta-analysis of yoga for low back pain. Clin J Pain. 2013;29(5):450-460. [pmid: 23246998].
31 Posadzki P, Ernst E. Yoga for low back pain: a systematic review of randomized clinical trials. Clin Rheumatol. 2011;30(9):1257-1262. [pmid: 21590293].
32 Cramer H, Krucoff C, Dobos G. Adverse events associated with yoga: a systematic review of published case reports and case series. PLoS One. 2013;8(10):e75515. [pmid: 24146758].
33 Jeter PE, Nkodo AF, Moonaz SH, Dagnelie G. A systematic review of yoga for balance in a healthy population. J Altern Complement Med. 2014;20(4):221-232. [pmid: 24517304].
34 Saper RB, Boah AR, Keosaian J, Cerrada C, Weinberg J, Sherman KJ. Comparing once- versus twice-weekly yoga classes for chronic low back pain in predominantly low income minorities: a randomized dosing trial. Evid Based Complement Alternat Med. 2013;2013. 658030.
35 Singh AK, Singh OP. A preliminary clinical evaluation of external snehan and asanas in the patients of sciatica. Int J Yoga. 2013;6(1):71-75. [pmid: 23439799].
36 Tekur P, Nagarathna R, Chametcha S, Hankey A, Nagendra HR. A comprehensive yoga programs improves pain, anxiety and depression in chronic low back pain patients more than exercise: an RCT. Complement Ther Med. 2012;20(3):107-118. [pmid: 22500659].
37 Saravanakumar P, Higgins IJ, Van Der Riet PJ, Marquez J, Sibbritt D. The influence of tai chi and yoga on balance and falls in a residential care setting: a randomised controlled trial. Contemp Nurse. 2014:5231-5255. [pmid: 25055894].
38 Tiedemann A, O'Rourke S, Sesto R, Sherrington C. A 12-week Iyengar yoga program improved balance and mobility in older community-dwelling people: a pilot randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2013;68(9):1068-1075. [pmid: 23825035].
39 Kinser PA, Bourguignon C, Whaley D, Hauenstein E, Taylor AG. Feasibility, acceptability, and effects of gentle Hatha yoga for women with major depression: findings from a randomized controlled mixed-methods study. Arch Psychiatr Nurs. 2013;27(3):137-147. [pmid: 23706890].
40 Sarubin N, Nothdurfter C, Schule C, et al. The influence of Hatha yoga as an add-on treatment in major depression on hypothalamic-pituitary-adrenal-axis activity: a randomized trial. J Psychiatr Res. 2014;53(1):76-83. [pmid: 24655586].
41 Gupta K, Mamidi P. A pilot study on certain yogic and naturopathic procedures in generalized anxiety disorder. International Journal of Research in Ayurveda and Pharmacy. 2013;4(6):858-861.
42 van der Kolk BA, Stone L, West J, et al. Yoga as an adjunctive treatment for posttraumatic stress disorder: a randomized controlled trial. J Clin Psychiatry. 2014;75(6):e559-565. [pmid: 25004196].
43 Mitchell KS, Dick AM, DiMartino DM, et al. A pilot study of a randomized controlled trial of yoga as an intervention for PTSD symptoms in women. J Trauma Stress. 2014;27(2):121-128. [pmid: 24668767].
44 Review Manager (RevMan) [Computer program]. Version 5.1. Copenhagen: The Nordic Cochrane Centre. The Cochrane Collaboration. 2011.
45 Cox H, Tilbrook H, Aplin J, et al. A randomised controlled trial of yoga for the treatment of chronic low back pain: results of a pilot study. Complement Ther Clin Pract. 2010;16(4):187-193. [pmid: 20920800].
46 Williams K, Abildso C, Steinberg L, et al. Evaluation of the effectiveness and efficacy of Iyengar yoga therapy on chronic low back pain. Spine (Phila Pa 1976). 2009;34(19):2066-2076. [pmid: 19701112].
47 Pushpika Attanayake AM, Somarathna KI, Vyas GH, Dash SC. Clinical evaluation of selected Yogic procedures in individuals with low back pain. Ayu. 2010;31(2):245-250. [pmid: 22131719].
48 Sherman KJ, Cherkin DC, Wellman RD, et al. A randomized trial comparing yoga, stretching, and a self-care book for chronic low back pain. Arch Intern Med. 2011;171(22):2019-2026. [pmid: 22025101].
49 Groessl EJ, Weingart KR, Johnson N, Baxi S. The benefits of yoga for women veterans with chronic low back pain. J Altern Complement Med. 2012;18(9):832-838. [pmid: 22812905].
50 Groessl EJ, Weingart KR, Aschbacher K, Pada L, Baxi S. Yoga for veterans with chronic low-back pain. J Altern Complement Med. 2008;14(9):1123-1129. [pmid: 18991515].
51 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. June 20, 2014.
52 Kozasa EH, Santos RF, Rueda AD, Benedito-Silva AA, De Ornellas FL, Leite JR. Evaluation of Siddha Samadhi Yoga for anxiety and depression symptoms: a preliminary study. Psychol Rep. 2008;103(1):271-274. [pmid: 18982958].
53 Michalsen A, Grossman P, Acil A, et al. Rapid stress reduction and anxiolysis among distressed women as a consequence of a three-month intensive yoga program. Med Sci Monit. 2005;11(12):CR555-561. [pmid: 16319785].
54 Vedamurthachar A, Janakiramaiah N, Hegde JM, et al. Antidepressant efficacy and hormonal effects of Sudarshana Kriya Yoga (SKY) in alcohol dependent individuals. J Affect Disord. 2006;94(1-3):249-253. [pmid: 16740317].
55 Sharma I, Azmi SA, Settiwar RM. Evaluation of the effect of pranayama in anxiety state. Altern Med. 1991;3(4):227-235.
56 Sahasi G, Mohan D, Kacker C. Effectiveness of yogic techniques in the management of anxiety. Journal of Personality and Clinical Studies. 1989;5(1):51-55.
57 Girodo M. Yoga meditation and flooding in the treatment of anxiety neurosis. J Behav Ther Exp Psychiatry. 1974;5(2):157-160.
58 Miller TM. The integration of short-term dynamic therapy and yoga in the treatment of generalized anxiety disorder and depression. Dissert Abstr Int B: Sci Eng. 2005;66(6-B):3419.
59 Woolery A, Myers H, Sternlieb B, Zeltzer L. A yoga intervention for young adults with elevated symptoms of depression. Altern Ther Health Med. 2004;10(2):60-63. [pmid: 15055096].
60 Javnbakht M, Hejazi Kenari R, Ghasemi M. Effects of yoga on depression and anxiety of women. Complement Ther Clin Pract. 2009;15(2):102-104. [pmid: 19341989].
61 van der Kolk BA. Clinical implications of neuroscience research in PTSD. Ann N Y Acad Sci. 2006;1071:277-293. [pmid: 16891578].
62 Dixon-Peters CA. The psychological effects of Hatha yoga on low-incomewomen who are survivors of domestic violence. Dissert Abstr Int B: Sci Eng. 2007;68(1-B):619.
63 Carter J, Byrne G. A two year study of the use of yoga in a series of pilot studies as an adjunct to ordinary psychiatric treatment in a group of Vietnam War veterans suffering from post traumatic stress disorder. 2004. http://www.therapywithyoga.com/Vivekananda.pdf. March 25, 2014.
64 Saper RB, Sherman KJ, Cullum-Dugan D, Davis RB, Phillips RS, Culpepper L. Yoga for chronic low back pain in a predominantly minority population: a pilot randomized controlled trial. Altern Ther Health Med. 2009;15(6):18-27. [pmid: 19943573].
65 Tilbrook HE, Cox H, Hewitt CE, et al. Yoga for chronic low back pain: a randomized trial. Ann Intern Med. 2011;155(9):569-578. [pmid: 22041945].
66 Williams KA, Petronis J, Smith D, et al. Effect of Iyengar yoga therapy for chronic low back pain. Pain. 2005;115(1-2):107-117. [pmid: 15836974].
67 Tekur P, Singphow C, Nagendra HR, Raghuram N. Effect of short-term intensive yoga program on pain, functional disability and spinal flexibility in chronic low back pain: a randomized control study. J Altern Complement Med. 2008;14(6):637-644. [pmid: 18673078].
68 Tekur P, Chametcha S, Hongasandra RN, Raghuram N. Effect of yoga on quality of life of CLBP patients: a randomized control study. Int J Yoga. 2010;3(1):10-17. [pmid: 20948896].
69 Butchart A, Kerr EA, Heisler M, Piette JD, Krein SL. Experience and management of chronic pain among patients with other complex chronic conditions. Clin J Pain. 2009;25(4):293-298. [pmid: 19590477].
70 Sinnott P, Wagner TH. Low back pain in VA users. Arch Intern Med. 2009;169(14):1338-1339. author reply 1339. [pmid: 19636039].
71 Freburger JK, Holmes GM, Agans RP, et al. The rising prevalence of chronic low back pain. Arch Intern Med. 2009;169(3):251-258. [pmid: 19204216].
72 Katz JN. Lumbar disc disorders and low-back pain: socioeconomic factors and consequences. J Bone Joint Surg Am. 2006;88(Suppl 2):21-24. [pmid: 16595438].
73 Deyo RA, Cherkin D, Conrad D, Volinn E. Cost, controversy, crisis: low back pain and the health of the public. Annu Rev Public Health. 1991;12:141-156. [pmid: 1828670].