# METHODS

Our protocol-directed approach was to begin by identifying recent relevant systematic reviews for each condition of interest, and to supplement these reviews by identifying any large (n≥100) randomized controlled trials (RCTs) not identified by the published reviews. We evaluated this literature to describe the breadth of studies assessing yoga for the health conditions of interest. In addition, where estimates of treatment effects were available from good-quality systematic reviews, we report these. The overall approach includes methods used in “overviews of reviews”12,13 and evidence mapping.9-11

## TOPIC DEVELOPMENT

This review was commissioned by the VA's Evidence-based Synthesis Program. The topic was nominated after a process that included a preliminary review of published peer-reviewed literature and consultation with investigators, VA and non-VA experts, and key stakeholders (Laura Krejci, Office of Patient Care Services; and Stephen Ezeji-Okoye, Veterans Administration Central Office Field Advisory Committee on Complementary and Alternative Medicine), with input from a technical expert panel. Clinical conditions were chosen in consultation with stakeholders for their high relevance to the Veteran population and the potential for yoga to benefit these conditions.

The final key questions were:

1. What are the extent, distribution, and methodological designs of intervention studies that evaluate yoga for the following conditions?
  - Low back pain
  - Prevention of falls
  - Mental illness:
    ○ Depressive disorders
    ○ Anxiety disorders (generalized anxiety disorder and panic disorder)
    ○ Posttraumatic stress disorder (PTSD)
  - Insomnia
2. What are the extent, distribution, and designs of studies that assess the adverse effects of yoga?

## SEARCH STRATEGY

We conducted separate searches for each health condition of interest using Medical Subject Headings (MeSH) terms, keywords, and selected free-text terms for yoga, systematic reviews, and RCTs, combined with terms for the health condition. This allowed us to gain an idea of the amount of literature available for each condition, as well as the degree of overlap in the literature across conditions. To ensure completeness, search strategies were developed in consultation with an experienced librarian and were conducted in PubMed, the Cochrane Database of Systematic Reviews, and Embase. Condition-specific searches were supplemented by a search of PubMed for systematic reviews that addressed the adverse effects associated with yoga and a search of the Allied and Complementary Medicine Database (AMED) using the single term “yoga.” The exact search strategies used are provided in Appendix B. When we did not identify any systematic reviews for eligible health conditions, we searched PROSPERO (an international prospective register of systematic review protocols) and the Cochrane Database for Systematic Reviews for protocols related to the specified health conditions. Searches were completed in July 2014.

## STUDY SELECTION

Using prespecified inclusion and exclusion criteria, 2 investigators assessed titles and abstracts for relevance to the key questions. Full-text articles identified by either investigator as potentially relevant were retrieved for further review and examined by 2 investigators against the eligibility criteria. Disagreements on inclusion or exclusion were resolved by discussion or by a third investigator. The criteria used to screen articles for inclusion or exclusion at both the title-and-abstract and full-text screening stages are detailed below. All results were tracked in both DistillerSR, a web-based data synthesis software program (Evidence Partners Inc., Manotick, ON, Canada), and EndNote® reference management software (version X5, Thomson Reuters, Philadelphia, PA).

Eligible studies had to meet the following inclusion criteria:

- Study designs: We included systematic reviews published from 2008 forward that evaluated yoga for one of the specified health conditions. Our goal was to identify current systematic reviews, as prior studies have shown that reviews can become out of date in 3 to 5 years.14-16 We also included RCTs (sample size ≥100 subjects) published since January 2011. The goal was to identify recent large RCTs that may not have been identified in published systematic reviews.
- Patients: Adults with low back pain (acute, chronic, or prevention of recurrence), at high risk of falls, or with depressive disorders, generalized anxiety disorder, panic disorder, PTSD, or insomnia. We used inclusive criteria for these conditions; for example, we included a range of depressive disorders, including subsyndromal depression (minor depression), adjustment disorder with depressed mood, and significant depressive symptoms as determined by a validated screening instrument.
- Interventions: Yoga generally consists of 3 components: 1) physical exercises and bodily positions or postures; 2) breath control practices; and 3) meditation. We included studies that self-identified the intervention as yoga, including yoga interventions that use exercises only for breath control, or have multiple components. We excluded studies that reviewed CAM therapies in general without a specific focus on yoga, as well reviews where yoga was only one of many interventions evaluated. Although mindfulness-based stress reduction and mindfulness-based cognitive therapy share some features with yoga, these therapies are mostly considered distinct from yoga and are typically reviewed separately from yoga. They were excluded from this review.
- Comparators: Any inactive control (waitlist, attention, or information control; or unenhanced usual care) or active comparator.
- Outcomes: Health outcomes including symptom severity, health-related quality of life, global measures of well-being, mortality, and adverse effects (including falls). We excluded studies that addressed solely mechanism of action, provider outcomes, patient acceptance, prevalence, use, or costs without reporting health outcomes as defined above.
- Timing: For RCTs, studies that reported follow-up of one month or greater. For systematic reviews, we accepted the outcome timing specified in the review's eligibility criteria.
- Settings: Healthcare-related or community settings.
- Limits: English-language publications.

## DATA ABSTRACTION

Data from published systematic reviews were abstracted into a customized Excel spreadsheet database by one investigator and verified by a second. Disagreements were resolved by consensus or by obtaining a third investigator's opinion when consensus could not be reached. Data elements included study characteristics (eg, search date, eligibility criteria, or assessment for publication bias), synthesis methods (eg, meta-analysis, sensitivity analyses), results (eg, number and design of included primary studies, sample characteristics, intervention characteristics, treatment effects, or risk of bias assessments), funding source, conflict of interest, and authors' conclusions (Appendix C).

## QUALITY ASSESSMENT

We used the following key quality criteria adapted from the Quality of Reporting of Meta-analyses (QUOROM)17 and Assessment of Multiple Systematic Reviews (AMSTAR)18 instruments to categorize each systematic review as good, fair, or poor quality (Appendix D):

- Search methods adequate for replication and comprehensive;
- Selection bias avoided;
- Data abstracted reliably;
- Characteristics of primary literature reported;
- Quality assessed appropriately;
- Results synthesized using appropriate methods;
- Publication bias assessed;
- Conflict of interest reported; and
- Conclusions supported by results.

Two investigators performed quality assessments independently. Disagreements were resolved between the 2 investigators by discussion.

We did not formally assess the quality of the primary literature; instead we relied on quality assessments as reported by the authors of the systematic reviews.

## DATA SYNTHESIS

We grouped the systematic reviews and RCTs by clinical topic and described them qualitatively. When there were multiple systematic reviews for a clinical topic, we created tables to describe the overlap in the primary studies. We then evaluated each unique primary study to determine if it evaluated yoga for a clinical condition of interest. Using this process for systematic reviews, coupled with our search for additional RCTs, we identified the total number of systematic reviews and unique primary studies applicable to each condition. We used systematic reviews, prioritizing the most recent good-quality review, to describe the number of studies, study designs, patient populations, intervention characteristics, and treatment effects. To evaluate treatment effects, we focused on RCTs. When non-RCTs were included in systematic reviews, we report descriptive data for these studies. When systematic reviews conducted meta-analyses, they reported treatment effects as standardized mean differences (SMDs). This approach is appropriate because the primary studies used differing scales to assess conceptually similar outcomes. The SMD is calculated by subtracting the average score of the treatment group from the average score of the control group and dividing the result by the pooled standard deviations of the 2 groups. SMDs of 0.2 can be considered small treatment effects; 0.5, moderate effects; and ≥0.8, large effects.19 Authors sometimes also reported Cochran's Q and I2 statistics, which are measures of heterogeneity, or variability, in treatment effect. The latter measure, the I2 statistic, describes the percentage of total variation across studies due to heterogeneity rather than to chance. A rough guide to interpreting the I2 statistic20 is:

- 0% to 40%: heterogeneity might not be important;
- 30% to 60%: may represent moderate heterogeneity;
- 50% to 90%: may represent substantial heterogeneity;
- 75% to 100%: considerable heterogeneity.

We evaluated the systematic reviews initially by condition, then used these results to create summary tables and figures that illustrate the number of RCTs, study characteristics, and estimates of treatment effect across conditions.

We used these data to make judgments about possible next steps for evaluating yoga for the clinical conditions of interest as follows:

- If no or only a few good-quality RCTs identified: consider RCTs.
- If >3 RCTs and no good-quality systematic review identified: consider a systematic review.
- If a good-quality systematic review along with subsequently published RCTs identified: consider using formal methods21,22 to determine the need for an updated review.
- If a good-quality systematic review, but no additional RCTs identified: consider surveillance of the primary literature to identify the need for an updated review.

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership. A transcript of their comments, along with our responses, is included in Appendix E.