# INTRODUCTION

Patient-centered care as practiced by the Veterans Health Administration (VHA) supports the active involvement of patients and their families in the decision-making process between options for treatment. Part of this mission is to identify, develop, and implement new practices and approaches that are found to be effective in promoting the transformation to a patient-centered model and improved patient care. Complementary and alternative medicine (CAM) strategies such as yoga are widely available in the private sector, and some Veterans have requested that the VHA make them available in the VA system. Determining the state of evidence on the benefits and harms of yoga and other CAM modalities is a priority for the VHA.

Yoga is a term used to describe a collection of spiritual and physical practices originating in ancient India and used to cultivate deep meditative states in order to achieve greater union with the divine or true self. Sometime around the second or third century CE, the 8-limbed path of yoga (Ashtanga yoga) was first documented, which includes the following practices: 1) Yama, or ethical restraints; 2) Niyama, or personal observances; 3) Asana, or physical exercises; 4) Pranayama, or mastery of breath; 5) Pratyahara, or sense withdrawal; 6) Dharana, or concentration; 7) Dhyana, or meditation; and 8) Samadhi, translated as ecstasy or nondualistic consciousness.1-3 By the 15th century, teachings describing the physical and mental aspects of yoga as purification practices in the context of Hinduism were compiled into a series of texts which include the Hatha Yoga Pradipika, Shiva Samhita, and Gherenda Samhita.4 The modern conception of Hatha yoga, which is most broadly associated with yoga in the west, derives from these texts.

There are numerous styles or lineages of yoga that were drawn from the traditions of the yoga sutras or Hatha yoga, and many of these have emerged in the past century. Styles such as Sivananda, Kripalu, Iyengar, Ashtanga, and Vinyasa provide a greater emphasis on physical and lifestyle practices, while styles such as Kundalini, Sahaj, and Siddha emphasize more esoteric aspects of yoga philosophy. In recent decades, numerous fitness-oriented yoga regimens, such as Power yoga, Yogafit, and Bikram yoga, have also gained popularity, particularly in the United States.5 As interest in the therapeutic applications of yoga expands, many of the interventions studied in the literature actually refer to particular techniques drawn from these various traditions. Examples of this include Sudarshan Kriya Yoga (SKY), which centers on rhythmic breathing practices; Kirtan Kriya, a meditative chanting exercise from Kundalini yoga; or yoga Nidra, a state of deep relaxation achieved through prescribed meditative techniques.6-8 A glossary of yoga terms is provided in Appendix A.

To fulfill the joint research needs of the Office of Patient Centered Care and the Field Advisory Committee on Complementary and Alternative Medicine, and to help VA leadership determine the most appropriate guidelines/policy for the implementation of CAM therapies within the VA, the Evidence-based Synthesis Program Coordinating Center proposed a CAM evidence mapping project to evaluate the existing evidence on yoga for common clinical conditions in Veterans. Evidence mapping is an emerging approach used to characterize evidence for a broad area of medicine.9-11 Evidence mapping can be defined as “the systematic organization and illustration of a broad field of research evidence,”10 with the goals of describing the breadth, depth, and methodology of published literature and identifying gaps in that literature. Evidence mapping differs from systematic reviews of the literature by covering broader topics and reporting on descriptive epidemiology of the literature rather than synthesizing evidence for a narrowly focused clinical question. It outlines the type and number of studies available in the literature and describes the basic features of the studies—location, design, population, intervention, and outcomes examined—but less commonly attempts to draw quantitative conclusions about treatment effects.

Through discussions with the key stakeholders, we prioritized an evidence map for: low back pain, prevention of falls, depressive disorders, anxiety disorders (generalized anxiety disorder and panic disorder), posttraumatic stress disorder (PTSD), and insomnia. In addition, we mapped the evidence for the adverse effects of yoga.