# Study Characteristics—Nonrandomized Studies of Yoga for Depressive Disorders

All studies included in the table below were evaluated in the systematic review by da Silva et al.1

Study | Design | Country | Participants | Condition | Yoga Style
Gangadhar, 2000^2^ | Non-RCT: Single-arm, open trial | NR | 20 | MDD | SKY
Janakiramaiah, 1998^3^ | Non-RCT: Single-arm, open trial | NR | 46 | Dysthymia | SKY
Lavey, 2005^4^ | Non-RCT: Single-arm, open trial | NR | 113 | Mood and non-mood disorders | Hatha
Miller, 2005^5^ | Non-RCT: Case series | NR | 3 | Depression and/or GAD | NR
Naga Venkatesha Murthy, 1997^6^ | Non-RCT: Single-arm, open trial | NR | 39 | MDD or dysthymia | SKY
Naga Venkatesha Murthy, 1998^7^ | Non-RCT: Single-arm, open trial | NR | 30 | MDD or dysthymia | SKY
Oretzky, 2007^8^ | Non-RCT: Comparative, controlled trial | NR | 58 | MDD | Vinyasa
Shapiro, 2007^9^ | Non-RCT: Single-arm, open trial | NR | 21 | MDD | Iyengar
| | | Total = 330

Abbreviations: GAD=generalized anxiety disorder; MDD=major depressive disorder; NR=not reported; RCT=randomized controlled trial; SKY=Sudarshana Kriya Yoga

## References to Appendix M

1 da Silva TL, Ravindran LN, Ravindran AV. Yoga in the treatment of mood and anxiety disorders: a review. Asian J Psychiatr. 2009;2(1):6-16. [pmid: 23051013].
2 Gangadhar BN, Janakiramaiah N, Sudarshan B, Shety KT. Stress-related biochemical effects of Sudarshan Kriya Yoga in depressed patients. Study #6. Presented at The Conference on Biological Psychiatry. New York NY. UN NGO Mental Health Committee. 2000.
3 Janakiramaiah N, Gangadhar BN, Naga Venkatesha Murthy PJ, et al. Therapeutic efficacy of Sudarshan Kriya Yoga (SKY) in dysthymic disorder. NIMHANS J. 1998;17(1):21-28.
4 Lavey R, Sherman T, Mueser KT, Osborne DD, Currier M, Wolfe R. The effects of yoga on mood in psychiatric inpatients. Psychiatric Rehabil J. 2005;28(4):399-402.
5 Miller TM. The integration of short-term dynamic therapy and yoga in the treatment of generalized anxiety disorder and depression. Diss Abstr Int B Sci Eng. 2005;66(6-B):3419.
6 Naga Venkatesha Murthy PJ, Gangadhar BN, Janakiramaiah N, Subbakrishna DK. Normalization of P300 amplitude following treatment in dysthymia. Biol Psychiatry. 1997;42(8):740-743. [pmid: 9325569].
7 Naga Venkatesha Murthy PJ, Janakiramaiah N, Gangadhar BN, Subbakrishna DK. P300 amplitude and antidepressant response to Sudarshan Kriya Yoga (SKY). J Affect Disord. 1998;50(1):45-48. [pmid: 9716279].
8 Oretzky S. The effects of yoga on elevated depressive and somatic symptoms in young adults. Diss Abstr Int B Sci Eng. 2007;67(9-B):5458.
9 Shapiro D, Cook IA, Davydov DM, Ottaviani C, Leuchter AF, Abrams M. Yoga as a complementary treatment of depression: effects of traits and moods on treatment outcome. Evid Based Complement Alternat Med. 2007;4(4):493-502. [pmid: 18227917].