# Study Characteristics—Randomized Controlled Trials of Yoga for Depressive Disorders

Study | Country | N | Condition | Yoga Style | Yoga Elements | Yoga Duration; Yoga (hrs/wk; time/session) | Comparator | Age; Sex | Included in Meta-analysis?
Broota, 1990^1^ | India | 30 | Clinician diagnosis | Broota Relaxation Technique | Breathing, postures | 3 days 20-25 min × 3 days | PMR | 19-49 NR | No
Butler, 2008^2^ | USA | 46 | DSM-IV; Dysthymia, chronic MDD, or double depression | Hatha | Meditation, breathing, postures | 8 wk 1 × 4-hr retreat; 8 × 2-hr group sessions; 1 booster session; home practice of 30 min, 6 days/wk | Group therapy with hypnosis | 50.4 (14.8) 74% female | Yes
Field, 2012^3^ | USA | 92 | DSM-IV, Prenatal | NR | Postures | 12 wk 20 min/wk | Social support group | 24.4 100% female | No
Field, 2012^4^ | USA | 84 | DSM-IV, Prenatal | NR | Postures | 12 wk 20 min/wk | Massage; Standard prenatal care | 26.6 100% female | Yes
Janakiramaiah, 2000^5^ | India | 45 | DSM-IV, HRSD ≥17 | SKY | Meditation, breathing | 4 wk 45 min/day × 6 days/wk (4.5 hr/wk) | ECT, Imipramine | 36.3 44% female | No
Khumar, 1993^6^ | India | 50 | “Severe depression” | Shavasana | Breathing | 30 days 30 min/day × 30 days (3.5 hr/wk) | WLC | 20-25 100% female, students | Yes
Lavretsky, 2013^7^ | USA | 45 | HRSD 5 to 17 | Kirtan Kriya | Meditation, breathing | 8 wk 12 min/day, 7 days/wk (1.4 hr/wk) | Relaxation music | 60.3 (14.8) 95% female | Yes
Rohini, 2000^8^ | India | 30 | DSM-IV, HRSD ≥18 | SKY | Meditation, breathing | 4 wk Daily, but min/session NR | Partial SKY | 31.9 (10.10) NR | Yes
Shahidi, 2011^9^ | Iran | 70 | GDS ≥10 | Laughter | Breathing, postures | 5 wk 10 × 30 min/session | Aerobic exercise; Unspecified control | 66.56 100% female | Yes
Sharma, 2005^10^ | India | 30 | DSM-IV MDD | Sahaj | Meditation | 8 wk 30 min/session, 3 x/wk (1.5 hr/wk) | Sitting quietly | 31.7 (8.6) 37% female | Yes
Veale, 1992^11^ | UK | 89 | CIS ≥17; CIS severity ≥2 | NR | Postures | 12 wk 3 session/wk; time/session NR | High-intensity aerobic exercise | 35.5 64% female | Yes
Woolery, 2004^12^ | USA | 28 | BDI 10-15 | Iyengar | Postures | 5 wk 1 hr/session; 2x/wk (2 hr/wk) | WLC | 21.5 (3.23) 79% female | Yes

Abbreviations: BDI=Beck Depression Inventory; CIS=Clinical Interview Schedule; DSM-IV=Diagnostic and Statistical Manual of Mental Disorders, 4th edition; ECT=electroconvulsive therapy; GDS=Geriatric Depression Scale; hr=hour(s); HRSD=Hamilton Rating Scale for Depression; MDD=major depressive disorder; min=minute(s); NR=not reported; PMR=progressive muscle relaxation; SKY=Sudarshan Kriya Yoga; wk=week(s); WLC=wait list control

## References to Appendix L

1 Broota A, Dhir R. Efficacy of two relaxation techniques in depression. J Pers Clin Stud. 1990;6(1):83-90.
2 Butler LD, Waelde LC, Hastings TA, et al. Meditation with yoga, group therapy with hypnosis, and psychoeducation for long-term depressed mood: a randomized pilot trial. J Clin Psychol. 2008;64(7):806-820. [pmid: 18459121].
3 Field T, Diego M, Delgado J, Medina L. Yoga and social support reduce prenatal depression, anxiety and cortisol. J Yoga PhysTher. 2012;2(124).
4 Field T, Diego M, Hernandez-Reif M, Medina L, Delgado J, Hernandez A. Yoga and massage therapy reduce prenatal depression and prematurity. J Bodyw Mov Ther. 2012;16(2):204-209. [pmid: 22464118].
5 Janakiramaiah N, Gangadhar BN, Naga Venkatesha Murthy PJ, Harish MG, Subbakrishna DK, Vedamurthachar A. Antidepressant efficacy of Sudarshan Kriya Yoga (SKY) in melancholia: a randomized comparison with electroconvulsive therapy (ECT) and imipramine. J Affect Disord. 2000;57(1-3):255-259. [pmid: 10708840].
6 Khumar SS, Kaur P, Kaur S. Effectiveness of Shavasana on depression among university students. Indian J Clin Psychol. 1993;20(2):82-87.
7 Lavretsky H, Epel ES, Siddarth P, et al. A pilot study of yogic meditation for family dementia caregivers with depressive symptoms: effects on mental health, cognition, and telomerase activity. Int J Geriatr Psychiatry. 2013;28(1):57-65. [pmid: 22407663].
8 Rohini V, Pandey RS, Janakiramaiah N, Gangadhar BN, Vedamuthachar A. A comparative study of full and partial Sudarshan Kriya Yoga (SKY) in major depressive disorder. NIMHANS J. 2000;18(1-2):53-57.
9 Shahidi M, Mojtahed A, Modabbernia A, et al. Laughter yoga versus group exercise program in elderly depressed women: a randomized controlled trial. Int J Geriatr Psychiatry. 2011;26(3):322-327. [pmid: 20848578].
10 Sharma VK, Das S, Mondal S, Goswampi U, Gandhi A. Effect of Sahaj Yoga on depressive disorders. Indian J Physiol Pharmacol. 2005;49(4):462-468. [pmid: 16579401].
11 Veale D, Le Fevre K, Pantelis C, de Souza V, Mann A, Sargeant A. Aerobic exercise in the adjunctive treatment of depression: a randomized controlled trial. J R Soc Med. 1992;85(9):541-544. [pmid: 1433121].
12 Woolery A, Myers H, Sternlieb B, Zeltzer L. A yoga intervention for young adults with elevated symptoms of depression. Altern Ther Health Med. 2004;10(2):60-63. [pmid: 15055096].