# Primary Studies Included in Systematic Reviews of Yoga for Depressive Disorders

Primary Study | Balasubraminiam, 2013^1^ | Cabral, 2011^2^ | da Silva, 2009^3^ | Cramer, 2013^4^
RCTs
Broota, 1990^5^ | - | - | X | X
Butler, 2008^6^ | - | X | X | X
*Field, 2012^7^ | - | - | - | X
Field, 2012^8^ | - | - | - | X
Janakiramaiah, 2000^9^ | - | X | X | X
Khumar, 1993^10^ | - | - | X | X
*Krishnamurthy, 2007^11^ | X | - | X | -
Lavretsky, 2013^12^ | - | - | - | X
Rohini, 2000^13^ | - | - | X | X
Shahidi, 2011^14^ | X | - | - | X
Sharma, 2005^15^ | - | - | X | X
Veale, 1992^16^ | - | - | - | X
*Vedamurthachar, 2006^17^ | X | X | - | -
Woolery, 2004^18^ | - | - | X | X
Nonrandomized studies
Gangadhar, 2000^19^ | - | - | X | -
Janakiramaiah, 1998^20^ | - | - | X | -
Kozasa, 2008^21^ | - | X | - | -
Lavey, 2005^22^ | - | - | X | -
Michalsen, 2005^23^ | - | X | X | -
Miller, 2005^24^ | - | - | X | -
Naga Venkatesha Murthy, 1997^25^ | - | - | X | -
Naga Venkatesha Murthy, 1998^26^ | - | - | X | -
Oretzky, 2007^27^ | - | - | X | -
Shapiro, 2007^28^ | - | - | X | -
Vedamurthachar, 2006^17^ | X | X | - | -

* Did not require depression for study entry but measured and reported depression severity.

Abbreviation: RCTs=randomized controlled trials

## References to Appendix K

1 Balasubramaniam M, Telles S, Doraiswamy PM. Yoga on our minds: a systematic review of yoga for neuropsychiatric disorders. Front Psychiatry. 2013;3:117. [pmid: 23355825].
2 Cabral P, Meyer HB, Ames D. Effectiveness of yoga therapy as a complementary treatment for major psychiatric disorders: a meta-analysis. Prim Care Companion CNS Disord. 2011;13(4).
3 da Silva TL, Ravindran LN, Ravindran AV. Yoga in the treatment of mood and anxiety disorders: a review. Asian J Psychiatr. 2009;2(1):6-16. [pmid: 23051013].
4 Cramer H, Lauche R, Langhorst J, Dobos G. Yoga for depression: a systematic review and meta-analysis. Depress Anxiety. 2013;30(11):1068-1083. [pmid: 23922209].
5 Broota A, Dhir R. Efficacy of two relaxation techniques in depression. J Pers Clin Stud. 1990;6(1):83-90.
6 Butler LD, Waelde LC, Hastings TA, et al. Meditation with yoga, group therapy with hypnosis, and psychoeducation for long-term depressed mood: a randomized pilot trial. J Clin Psychol. 2008;64(7):806-820. [pmid: 18459121].
7 Field T, Diego M, Delgado J, Medina L. Yoga and social support reduce prenatal depression, anxiety and cortisol. J Yoga PhysTher. 2012;2(124).
8 Field T, Diego M, Hernandez-Reif M, Medina L, Delgado J, Hernandez A. Yoga and massage therapy reduce prenatal depression and prematurity. J Bodyw Mov Ther. 2012;16(2):204-209. [pmid: 22464118].
9 Janakiramaiah N, Gangadhar BN, Naga Venkatesha Murthy PJ, Harish MG, Subbakrishna DK, Vedamurthachar A. Antidepressant efficacy of Sudarshan Kriya Yoga (SKY) in melancholia: a randomized comparison with electroconvulsive therapy (ECT) and imipramine. J Affect Disord. 2000;57(1-3):255-259. [pmid: 10708840].
10 Khumar SS, Kaur P, Kaur S. Effectiveness of Shavasana on depression among university students. Indian J Clin Psychol. 1993;20(2):82-87.
11 Krishnamurthy MN, Telles S. Assessing depression following two ancient Indian interventions: effects of yoga and ayurveda on older adults in a residential home. J Gerontol Nurs. 2007;33(2):17-23. [pmid: 17310659].
12 Lavretsky H, Epel ES, Siddarth P, et al. A pilot study of yogic meditation for family dementia caregivers with depressive symptoms: effects on mental health, cognition, and telomerase activity. Int J Geriatr Psychiatry. 2013;28(1):57-65. [pmid: 22407663].
13 Rohini V, Pandey RS, Janakiramaiah N, Gangadhar BN, Vedamuthachar A. A comparative study of full and partial Sudarshan Kriya Yoga (SKY) in major depressive disorder. NIMHANS J. 2000;18(1-2):53-57.
14 Shahidi M, Mojtahed A, Modabbernia A, et al. Laughter yoga versus group exercise program in elderly depressed women: a randomized controlled trial. Int J Geriatr Psychiatry. 2011;26(3):322-327. [pmid: 20848578].
15 Sharma VK, Das S, Mondal S, Goswampi U, Gandhi A. Effect of Sahaj Yoga on depressive disorders. Indian J Physiol Pharmacol. 2005;49(4):462-468. [pmid: 16579401].
16 Veale D, Le Fevre K, Pantelis C, de Souza V, Mann A, Sargeant A. Aerobic exercise in the adjunctive treatment of depression: a randomized controlled trial. J R Soc Med. 1992;85(9):541-544. [pmid: 1433121].
17 Vedamurthachar A, Janakiramaiah N, Hegde JM, et al. Antidepressant efficacy and hormonal effects of Sudarshana Kriya Yoga (SKY) in alcohol dependent individuals. J Affect Disord. 2006;94(1-3):249-253. [pmid: 16740317].
18 Woolery A, Myers H, Sternlieb B, Zeltzer L. A yoga intervention for young adults with elevated symptoms of depression. Altern Ther Health Med. 2004;10(2):60-63. [pmid: 15055096].
19 Gangadhar BN, Janakiramaiah N, Sudarshan B, Shety KT. Stress-related biochemical effects of Sudarshan Kriya Yoga in depressed patients. Study #6. Presented at The Conference on Biological Psychiatry. New York NY. UN NGO Mental Health Committee. 2000.
20 Janakiramaiah N, Gangadhar BN, Naga Venkatesha Murthy PJ, et al. Therapeutic efficacy of Sudarshan Kriya Yoga (SKY) in dysthymic disorder. NIMHANS J. 1998;17(1):21-28.
21 Kozasa EH, Santos RF, Rueda AD, Benedito-Silva AA, De Ornellas FL, Leite JR. Evaluation of Siddha Samadhi Yoga for anxiety and depression symptoms: a preliminary study. Psychol Rep. 2008;103(1):271-274. [pmid: 18982958].
22 Lavey R, Sherman T, Mueser KT, Osborne DD, Currier M, Wolfe R. The effects of yoga on mood in psychiatric inpatients. Psychiatric Rehabil J. 2005;28(4):399-402.
23 Michalsen A, Grossman P, Acil A, et al. Rapid stress reduction and anxiolysis among distressed women as a consequence of a three-month intensive yoga program. Med Sci Monit. 2005;11(12):CR555-561. [pmid: 16319785].
24 Miller TM. The integration of short-term dynamic therapy and yoga in the treatment of generalized anxiety disorder and depression. Diss Abstr Int B Sci Eng. 2005;66(6-B):3419.
25 Naga Venkatesha Murthy PJ, Gangadhar BN, Janakiramaiah N, Subbakrishna DK. Normalization of P300 amplitude following treatment in dysthymia. Biol Psychiatry. 1997;42(8):740-743. [pmid: 9325569].
26 Naga Venkatesha Murthy PJ, Janakiramaiah N, Gangadhar BN, Subbakrishna DK. P300 amplitude and antidepressant response to Sudarshan Kriya Yoga (SKY). J Affect Disord. 1998;50(1):45-48. [pmid: 9716279].
27 Oretzky S. The effects of yoga on elevated depressive and somatic symptoms in young adults. Diss Abstr Int B Sci Eng. 2007;67(9-B):5458.
28 Shapiro D, Cook IA, Davydov DM, Ottaviani C, Leuchter AF, Abrams M. Yoga as a complementary treatment of depression: effects of traits and moods on treatment outcome. Evid Based Complement Alternat Med. 2007;4(4):493-502. [pmid: 18227917].