# Study Characteristics—Randomized Controlled Trials of Yoga for Low Back Pain

Study | Country | N | Condition | Yoga Style | Yoga Elements | Yoga Duration; Yoga Hours per Week | Comparator | Age; Sex | Included in Meta-analysis?
Cox, 2010^1^ | UK | 20 | LBP at least 3 mo; RMDQ>4; no spinal surgery | Specialized Iyengar for back pain (relaxation, postures) | Meditation, breathing, postures | 12 wk, 75 min weekly, homework regular practice + booklet “the back book” + usual care | WLC + booklet “the back book” + usual care for 12 wk | 45 65% female | Yes, short-term pain, back-specific disability and HRQOL
Galantino, 2004^2^ | USA | 22 | LBP at least 6 mo; min of 2 conservative treatments without long term relief | Hatha yoga (stretching postures, asanas, breathing, relaxation, meditation) | Meditation, breathing, postures | 6 wk, 60 min 2×/wk | WLC; usual care allowed for 6 wk | 30-65 77.3% female | Yes, short-term back-specific disability
Pushpika Attanayake, 2010^3^ | India | 12 | LBP at least 3 wk; no specific causes, no neurological symptoms; no major concomitant illness | Asanas, prayer, chanting, pranayama | Meditation, breathing, postures | 3 wk, 60 min/wk + lifestyle and dietary changes | Lifestyle and dietary changes (exercise, prayer, chanting); 3 wk | 30-49 NR | No, excluded due to high bias
Saper, 2009^4^ | USA | 30 | Muscular LBP at least 12 wk; pain intensity 2 wk before >4 (0-10 NRS); no back surgery within last 3 yr | Hatha yoga (breathing, asanas, relaxation) | Meditation, breathing, postures | 12 wk, 75 min/wk | WLC, routine care allowed + book for 12 wk | 44(13) 83% female | Yes, long- and short-term pain, back-specific disability, and HRQOL
Sherman, 2005^5^ | USA | 101 | Muscular LBP at least 12 wk | Viniyoga (breathing, postures, relaxation) | Breathing, postures | 12 wk, 75 min/wk | 1. Exercise (education, aerobics and strengthen-ing) 12 wk, 75 min/wk; 2. Book (exercise, fitness, lifestyle advice) for home use 12 wk | 44(12) 66% female | No
Sherman, 2011^6^ | USA | 228 | Muscular LBP at least 12 wk; bothersome >3 (0-10 NRS) | Viniyoga (breathing, postures, relaxation) | Breathing, postures | 12 wk 75 min/wk | 1. Exercise (education, aerobic and strengthen-ing) 12 wk, 75 min/wk; 2. Book (exercise, fitness, lifestyle advice) for home use 12 wk | 48.1 (9.8) NR | Yes, short- and long-term pain and back-specific disability
Tekur, 2008^7^ and Tekur, 2010^8^ | India | 80 | LBP at least 3 mo; inpatients in a healthcare center; no radiating pain to the leg or organic pathology | Yoga (meditation, chanting, physical practice, lectures) | Meditation, breathing, postures | 1 wk, daily practice + vegetarian diet | PT exercise 1 wk, daily practice + vegetarian diet | 49 (3.6) 45% female | Yes, short-term back-specific disability and HRQOL. Results from Tekur, 2008^7^ and Tekur, 2010^8^ combined.
Tilbrook, 2011^9^ | UK | 313 | LBP at least 3 mo RMDQ >4, no spine surgery | Yoga (asanas, pranayamas, relaxation, mental focus, philosophy | Meditation, breathing, postures | 12 wk, 75 min/wk | WLC + back pain education book 12 wk | 46.3(1.5) 70.3% female | Yes, long- and short-term pain, back-specific disability and HRQOL
Williams, 2005^10^ | USA | 60 | LBP at least 3 mo, no organic origin | Iyengar yoga | Postures | 16 wk, 90 min/wk; 30 min practice 5 days/wk + weekly newsletters on back care and 2 × 60-min lectures with handouts | Education control; weekly newsletters on back care, 2 × 60-min lectures, handouts on PT for 16 wk | 48(2) 68.2% female | Yes, short- and long-term pain and back-specific disability
Williams, 2009^11^ | USA | 90 | LBP at least 3 mo. no organic origin | Iyengar yoga | Postures | 24 wk, 90 min 2×/wk; homework 30 min daily | Self-directed SMC 24 wk | 48(11.1) 76.7% female | Yes, short- and long-term pain and back-specific disability

Abbreviations: HRQOL=health-related quality of life; LBP=low back pain; min=minute(s); mo=month(s); NR=not reported; NRS=Numeric Rating Scale; PT=physical therapy; RMDQ=Roland-Morris Disability Questionnaire; SMC=standard medical care; wk=week(s); WLC=wait list control; yr=year(s)

## References to Appendix J

1 Cox H, Tilbrook H, Aplin J, et al. A randomised controlled trial of yoga for the treatment of chronic low back pain: results of a pilot study. Complement Ther Clin Pract. 2010;16(4):187-193. [pmid: 20920800].
2 Galantino ML, Bzdewka TM, Eissler-Russo JL, et al. The impact of modified Hatha yoga on chronic low back pain: a pilot study. Altern Ther Health Med. 2004;10(2):56-59. [pmid: 15055095].
3 Pushpika Attanayake AM, Somarathna KI, Vyas GH, Dash SC. Clinical evaluation of selected Yogic procedures in individuals with low back pain. Ayu. 2010;31(2):245-250. [pmid: 22131719].
4 Saper RB, Sherman KJ, Cullum-Dugan D, Davis RB, Phillips RS, Culpepper L. Yoga for chronic low back pain in a predominantly minority population: a pilot randomized controlled trial. Altern Ther Health Med. 2009;15(6):18-27. [pmid: 19943573].
5 Sherman KJ, Cherkin DC, Erro J, Miglioretti DL, Deyo RA. Comparing yoga, exercise, and a self-care book for chronic low back pain: a randomized, controlled trial. Ann Intern Med. 2005;143(12):849-856. [pmid: 16365466].
6 Sherman KJ, Cherkin DC, Wellman RD, et al. A randomized trial comparing yoga, stretching, and a self-care book for chronic low back pain. Arch Intern Med. 2011;171(22):2019-2026. [pmid: 22025101].
7 Tekur P, Singphow C, Nagendra HR, Raghuram N. Effect of short-term intensive yoga program on pain, functional disability and spinal flexibility in chronic low back pain: a randomized control study. J Altern Complement Med. 2008;14(6):637-644. [pmid: 18673078].
8 Tekur P, Chametcha S, Hongasandra RN, Raghuram N. Effect of yoga on quality of life of CLBP patients: A randomized control study. Int J Yoga. 2010;3(1):10-17. [pmid: 20948896].
9 Tilbrook HE, Cox H, Hewitt CE, et al. Yoga for chronic low back pain: a randomized trial. Ann Intern Med. 2011;155(9):569-578. [pmid: 22041945].
10 Williams KA, Petronis J, Smith D, et al. Effect of Iyengar yoga therapy for chronic low back pain. Pain. 2005;115(1-2):107-117. [pmid: 15836974].
11 Williams K, Abildso C, Steinberg L, et al. Evaluation of the effectiveness and efficacy of Iyengar yoga therapy on chronic low back pain. Spine (Phila Pa 1976). 2009;34(19):2066-2076. [pmid: 19701112].