# Primary Studies Included in Systematic Reviews of Yoga for Low Back Pain

Primary Study (all RCTs) | Holtzman, 2013^1^ | Cramer, 2013^2^ | Posadzki, 2011^3^
Cox, 2010^4^ | - | X | X
Galantino, 2004^5^ | X | X | X
Pushpika Attanayake, 2010^6^ | - | X | -
Saper, 2009^7^ | X | X | X
Sherman, 2005^8^ | X | X | X
Sherman, 2011^9^ | X | - | -
Tekur, 2008^10^ | X | X | X
Tekur, 2010^11^ | - | X | -
Tilbrook, 2011^12^ | X | X | -
Williams, 2005^13^ | X | X | X
Williams, 2009^14^ | X | X | X

Abbreviation: RCTs=randomized controlled trials

## References to Appendix I

1 Holtzman S, Beggs RT. Yoga for chronic low back pain: a meta-analysis of randomized controlled trials. Pain Res Manag. 2013;18(5):267-272. [pmid: 23894731].
2 Cramer H, Lauche R, Haller H, Dobos G. A systematic review and meta-analysis of yoga for low back pain. Clin J Pain. 2013;29(5):450-460. [pmid: 23246998].
3 Posadzki P, Ernst E. Yoga for low back pain: a systematic review of randomized clinical trials. Clin Rheumatol. 2011;30(9):1257-1262. [pmid: 21590293].
4 Cox H, Tilbrook H, Aplin J, et al. A randomised controlled trial of yoga for the treatment of chronic low back pain: results of a pilot study. Complement Ther Clin Pract. 2010;16(4):187-193. [pmid: 20920800].
5 Galantino ML, Bzdewka TM, Eissler-Russo JL, et al. The impact of modified Hatha yoga on chronic low back pain: a pilot study. Altern Ther Health Med. 2004;10(2):56-59. [pmid: 15055095].
6 Pushpika Attanayake AM, Somarathna KI, Vyas GH, Dash SC. Clinical evaluation of selected Yogic procedures in individuals with low back pain. Ayu. 2010;31(2):245-250. [pmid: 22131719].
7 Saper RB, Sherman KJ, Cullum-Dugan D, Davis RB, Phillips RS, Culpepper L. Yoga for chronic low back pain in a predominantly minority population: a pilot randomized controlled trial. Altern Ther Health Med. 2009;15(6):18-27. [pmid: 19943573].
8 Sherman KJ, Cherkin DC, Erro J, Miglioretti DL, Deyo RA. Comparing yoga, exercise, and a self-care book for chronic low back pain: a randomized, controlled trial. Ann Intern Med. 2005;143(12):849-856. [pmid: 16365466].
9 Sherman KJ, Cherkin DC, Wellman RD, et al. A randomized trial comparing yoga, stretching, and a self-care book for chronic low back pain. Arch Intern Med. 2011;171(22):2019-2026. [pmid: 22025101].
10 Tekur P, Singphow C, Nagendra HR, Raghuram N. Effect of short-term intensive yoga program on pain, functional disability and spinal flexibility in chronic low back pain: a randomized control study. J Altern Complement Med. 2008;14(6):637-644. [pmid: 18673078].
11 Tekur P, Chametcha S, Hongasandra RN, Raghuram N. Effect of yoga on quality of life of CLBP patients: A randomized control study. Int J Yoga. 2010;3(1):10-17. [pmid: 20948896].
12 Tilbrook HE, Cox H, Hewitt CE, et al. Yoga for chronic low back pain: a randomized trial. Ann Intern Med. 2011;155(9):569-578. [pmid: 22041945].
13 Williams KA, Petronis J, Smith D, et al. Effect of Iyengar yoga therapy for chronic low back pain. Pain. 2005;115(1-2):107-117. [pmid: 15836974].
14 Williams K, Abildso C, Steinberg L, et al. Evaluation of the effectiveness and efficacy of Iyengar yoga therapy on chronic low back pain. Spine (Phila Pa 1976). 2009;34(19):2066-2076. [pmid: 19701112].