# Otherwise Eligible Randomized Controlled Trials with n<100

Study (by Condition) | Number of Participants
Low Back Pain
Saper, 2013^1^ | N=95
Singh, 2013^2^ | N=60
Tekur, 2012^3^ | N=80
Prevention of Falls
Tiedemann, 2013^4^ | N=54
*Saravanakumar, 2014^5^ | N=unknown (full text of publication not available)
Mental Illness: Depressive Disorders
Kinser, 2013^6^ | N=27
Sarubin, 2014^7^ | N=60
Mental Illness: Anxiety Disorders (GAD and PD)
Gupta, 2013^8^ | N=12
Mental Illness: PTSD
Mitchell, 2014^9^ | N=38
van der Kolk, 2014^10^ | N=64
Insomnia
(No studies) | –

* Abstract promising, but does not report number of participants. An introduction available online (http://www.contemporarynurse.com/archives/vol/48/issue/1/article/5489/the-influence-of-tai-chi-and-yoga-on-balance-and) states, “We present the preliminary results from assessments in a small randomised cohort of older adults in a residential care facility”. We were unable to obtain a copy of the full text of the article.

Abbreviations: GAD=generalized anxiety disorder; PD=panic disorder; PTSD=posttraumatic stress disorder

## References to Appendix H

1 Saper RB, Boah AR, Keosaian J, Cerrada C, Weinberg J, Sherman KJ. Comparing once- versus twice-weekly yoga classes for chronic low back pain in predominantly low income minorities: a randomized dosing trial. Evid Based Complement Alternat Med. 2013;2013. 658030.
2 Singh AK, Singh OP. A preliminary clinical evaluation of external snehan and asanas in the patients of sciatica. Int J Yoga. 2013;6(1):71-75. [pmid: 23439799].
3 Tekur P, Nagarathna R, Chametcha S, Hankey A, Nagendra HR. A comprehensive yoga programs improves pain, anxiety and depression in chronic low back pain patients more than exercise: an RCT. Complement Ther Med. 2012;20(3):107-118. [pmid: 22500659].
4 Tiedemann A, O'Rourke S, Sesto R, Sherrington C. A 12-week Iyengar yoga program improved balance and mobility in older community-dwelling people: a pilot randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2013;68(9):1068-1075. [pmid: 23825035].
5 Saravanakumar P, Higgins IJ, Van Der Riet PJ, Marquez J, Sibbritt D. The influence of tai chi and yoga on balance and falls in a residential care setting: a randomised controlled trial. Contemp Nurse. 2014:5231-5255. [pmid: 25055894].
6 Kinser PA, Bourguignon C, Whaley D, Hauenstein E, Taylor AG. Feasibility, acceptability, and effects of gentle Hatha yoga for women with major depression: findings from a randomized controlled mixed-methods study. Arch Psychiatr Nurs. 2013;27(3):137-147. [pmid: 23706890].
7 Sarubin N, Nothdurfter C, Schule C, et al. The influence of Hatha yoga as an add-on treatment in major depression on hypothalamic-pituitary-adrenal-axis activity: a randomized trial. J Psychiatr Res. 2014;53(1):76-83. [pmid: 24655586].
8 Gupta K, Mamidi P. A pilot study on certain yogic and naturopathic procedures in generalized anxiety disorder. International Journal of Research in Ayurveda and Pharmacy. 2013;4(6):858-861.
9 Mitchell KS, Dick AM, DiMartino DM, et al. A pilot study of a randomized controlled trial of yoga as an intervention for PTSD symptoms in women. J Trauma Stress. 2014;27(2):121-128. [pmid: 24668767].
10 van der Kolk BA, Stone L, West J, et al. Yoga as an adjunctive treatment for posttraumatic stress disorder: a randomized controlled trial. J Clin Psychiatry. 2014;75(6):e559-565. [pmid: 25004196].