# Quality of Included Systematic Reviews

Quality Criterion | Lower Back Pain | | | Prevention of Falls | Mental Illness and Insomnia | | | | Adverse Effects
Quality Criterion | Cramer, 2013^1^ | Holtzman, 2013^2^ | Posadzki, 2011^3^ | Jeter, 2014^4^ | Balasubramaniam, 2013^5^ | Cabral, 2011^6^ | Cramer, 2013^7^ | da Silva, 2009^8^ | Cramer, 2013^9^
1 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes
2 | Yes | Yes | Yes/No? | Yes | Yes | No | Yes | No | Yes
3 | Yes | Yes | Yes | Yes | No | No | Yes | No | Yes
4 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes
5 | Yes | Can't tell | Yes | No | Can't tell | Can't tell | Yes | Can't tell | Can't tell
6 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes^*^
7 | Yes | Yes | Yes | Yes | Yes | No | Yes | No | N/A
8 | Yes | Yes | N/A or Yes? | N/A | Can't tell | No | Yes | Can't tell | N/A
9 | Yes | Yes | Yes | Yes | Yes | No | Yes | No | N/A
10 | Yes | No | No or Can't tell? | No | Yes | No | Can't tell | No | N/A
11 | Yes | No | Yes | Yes | Can't tell | Yes | Yes | No | Yes
12 | Yes | Yes | Yes | Yes | Yes | No | Yes | Can't tell | Yes
Overall | Good | Good | Good | Good | Fair | Poor | Good | Poor | Good

* Demographic information limited.

Abbreviation: N/A=not applicable

## References to Appendix G

1 Cramer H, Lauche R, Haller H, Dobos G. A systematic review and meta-analysis of yoga for low back pain. Clin J Pain. 2013;29(5):450-460. [pmid: 23246998].
2 Holtzman S, Beggs RT. Yoga for chronic low back pain: a meta-analysis of randomized controlled trials. Pain Res Manag. 2013;18(5):267-272. [pmid: 23894731].
3 Posadzki P, Ernst E. Yoga for low back pain: a systematic review of randomized clinical trials. Clin Rheumatol. 2011;30(9):1257-1262. [pmid: 21590293].
4 Jeter PE, Nkodo AF, Moonaz SH, Dagnelie G. A systematic review of yoga for balance in a healthy population. J Altern Complement Med. 2014;20(4):221-232. [pmid: 24517304].
5 Balasubramaniam M, Telles S, Doraiswamy PM. Yoga on our minds: a systematic review of yoga for neuropsychiatric disorders. Front Psychiatry. 2013;3:117. [pmid: 23355825].
6 Cabral P, Meyer HB, Ames D. Effectiveness of yoga therapy as a complementary treatment for major psychiatric disorders: a meta-analysis. Prim Care Companion CNS Disord. 2011;13(4). PCC.10r01068.
7 Cramer H, Lauche R, Langhorst J, Dobos G. Yoga for depression: a systematic review and meta-analysis. Depress Anxiety. 2013;30(11):1068-1083. [pmid: 23922209].
8 da Silva TL, Ravindran LN, Ravindran AV. Yoga in the treatment of mood and anxiety disorders: a review. Asian J Psychiatr. 2009;2(1):6-16. [pmid: 23051013].
9 Cramer H, Krucoff C, Dobos G. Adverse events associated with yoga: a systematic review of published case reports and case series. PLoS One. 2013;8(10):e75515. [pmid: 24146758].