# Potentially Relevant Trials Identified in ClinicalTrials.gov

Title | Status | ClinicalTrials.gov Identifier
Low Back Pain
The Effect of Yoga in Chronic Low Back Pain | Completed, no publication; n=10 | NCT01963871
Yoga vs. Physical Therapy vs. Education for Chronic Low Back Pain in Minority Populations | Ongoing; planned n=230 | NCT01343927
Prevention of Falls
Yoga Exercise for Improving Balance in Patients With Subacute & Chronic Stroke | Completed, no publication; n=40 | NCT01806922
Mental Illness: Depressive Disorders
Yoga in Unipolar and Bipolar Disorders | Completed, no publication; n=90 | NCT00482482
Treating Depression With Yoga | Completed, no publication; n=40 | NCT01210651
Holistic Approaches to Depression | Ongoing; planned n=150 | NCT01384916
Mental Illness: Anxiety Disorders (GAD and PD)
GATE: Generalized Anxiety - A Treatment Evaluation | Ongoing; planned n=230 | NCT01912287
Mental Illness: PTSD
Evaluation of a Yoga Intervention for Post-Traumatic Stress Disorder (EYIPTSD) | Completed, no publication; n=108 | NCT00962403
Complementary and Alternative Interventions for Veterans With Posttraumatic Stress Disorder | Ongoing; planned n=200 | NCT01512303
Mindful Yoga Therapy for Veterans With PTSD and Pain | Ongoing; planned n=30 | NCT01957371
Mindful Yoga Therapy as an Adjunctive Treatment for PTSD Among OEF/OIF Veterans | Ongoing; planned n=30 | NCT01521442
Insomnia
Evaluation of Yoga for Sleep Disturbances in Post Traumatic Stress Disorder (PTSD) | Completed, no publication; n=50 | NCT01556074
Yoga as a Treatment for Insomnia | Completed, no publication; n=48 | NCT00033865
Yoga or Educational Wellness Class for Women With Stage I, Stage II, or Stage III Breast Cancer Undergoing Chemotherapy | Completed, no publication; n=40 | NCT00994279
Improving Sleep and Quality of Life in Adults With HIV Disease | Completed, no publication; n=20 | NCT01073423

Abbreviations: GAD=generalized anxiety disorder; HIV= human immunodeficiency virus; OEF/OIF=Operation Enduring Freedom/Operation Iraqi Freedom; PD=panic disorder; PTSD=posttraumatic stress disorder