# Peer Review Comments/Author Responses

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | Yes | Acknowledged
2 | Yes | Acknowledged
3 | Yes. The methods implemented, though clearly stated, may not be appropriate as they are utilizing a pill vs. placebo paradigm to evaluate research where that paradigm may not be useful. | We chose to prioritize RCTs as the study design best suited to evaluating treatment effects. We included studies evaluating yoga against any comparator.
4 | Yes | Acknowledged
5 | Yes. I thought it was reasonable to focus on the most recent review and include large RCTs. | Acknowledged; thank you.
6 | Reviewer gave all comments generally; included under Question 4, below | (See below, under Question 4)
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | No. This is an excellent effort to look at all the data available on Yoga for these disorders. | Thank you.
1 | My only concern, having done two reviews myself, is why two people did not do the data extraction? I think it eliminates bias. In the reviews I did, two separate researchers extracted the data (found articles) from the data bases. | We have revised the document to clarify that 2 reviewers independently identified potentially eligible studies at both the title-and-abstract screening stage and the full-text screening stage, and that 2 investigators were involved in data extraction for each included study.
1 | I take a little exception to having one of the studies I was involved with labeled as “low” (Cabral reviewed under anxiety, PTSD) in terms of the quality of the review, as I personally know great pains were taken to have 2 independent people go through the research available to find the papers targeted by our search criteria. | We applied criteria described in Appendix D to ascribe a quality rating score to each included systematic review. The authors of the review by Cabral et al stated a focused clinical question, avoided selection bias, reported the characteristics of the included studies, and disclosed potential conflicts of interest, but our assessment was that this review did not meet other quality criteria that we consider to be required for a “good” or “fair” quality rating.
1 | I am unclear about why MBSR was not included in the review. Is its focus on “Meditation” what causes it to be excluded? I am aware of a comprehensive MBSR program being provided at my VA so think it would be very useful for MBSR articles to be included. | We considered including MBSR in the review because it typically includes breathing exercises that share features or general principles with yoga. We decided, however, that including all practices that share features with yoga (including MBSR, all meditation practices, and focused breathing exercises) would significantly shift the focus of the review away from yoga, thereby resulting in findings that would not be directly applicable to the key questions. This approach is consistent with reviews of yoga and reviews of MBSR, which typically do not include yoga interventions. We added this rationale to the Methods section.
2 | No | Acknowledged
3 | Yes. The bias is in the inclusion exclusion criteria, not in the synthesis of the evidence. To exclude 79 out of 89 articles may indicate that the established criteria used did not fit this area of research – at least not at this early stage in yoga research. The report is potentially overlooking valuable evidence that was excluded based on numbers, not on quality of science that might be beneficial in leading the field forward. | We acknowledge that some of the published literature that pertains to yoga is not included or reflected in our review. For the purpose of this mapping report, the stakeholders and investigators decided to apply inclusion criteria a priori, which led to the exclusion of studies that were not recent RCTs or systematic reviews. The quality of the science of some of these excluded studies may have been relatively high, but we set out to map the published literature as reflected by systematic reviews and recent RCTs.
4 | No | Acknowledged
5 | No. Although the authors did a good job in this, I am aware that at least some of the systematic reviews inaccurately describe the quality of the primary studies. I don't think this has affected the outcomes. | We carefully described the systematic review authors' approach to quality assessment of primary studies and included this characteristic in our quality ratings of the systematic review. The 2 reviews that evaluated the majority of the primary trials had good approaches to quality assessment.
6 | Reviewer gave all comments generally; included under Question 4, below | (See below, under Question 4)
Question 3: Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | Yes. Yoga as an adjunctive treatment for posttraumatic stress disorder: a randomized controlled trial. van der Kolk BA, Stone L, West J, Rhodes A, Emerson D, Suvak M, Spinazzola J. J Clin Psychiatry. Jun. 2014;75(6):e559-65. [doi: 10.4088/JCP.13m08561]. [pmid: 25004196]. [pmid: 25004196]. | We updated the literature search through July 30, 2014. The updated search identified this study, which would have been eligible except that it had a sample size <100 (n=64). As stated below (see Question 4, response to comment from Reviewer 3), although we did not evaluate RCTs with n<100 published after 2011, we have now identified and cited these studies. Given the small number of otherwise eligible RCTs with n<100 identified (n=10), omission of these studies would not change any conclusions.
2 | No. Not that I'm aware of. | Acknowledged
3 | No | Acknowledged
4 | Yes. See #4 below and attached pdf. (Meyer et al. 2012) | (See below, under Question 4)
5 | No. I don't know of any. There are some trials currently being conducted, so some of these gaps may be diminished in the next few years. | Acknowledged
6 | Reviewer gave all comments generally; included under Question 4, below | (See below, under Question 4)
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | No comments | Acknowledged
2 | No comments | Acknowledged
3 | I would suggest looking at smaller RCT and pre-2011 RCTs to see if that changes the outcome of the report in the areas of effectiveness, applicability, and informing research gaps. | The systematic reviews included in this review did not exclude primary studies by sample size; we therefore expect most of the pertinent pre-2011 RCTs to be reflected in this review. Although we did not evaluate RCTs with n<100 published after 2011, we have now identified and cited these studies. Given the small number of otherwise eligible RCTs with n<100 identified (n=10), omission of these studies would not change any conclusions.
4 | For Fig. ES-1 and Fig 2, the ordinate is so large that the N=11 for PTSD looks like zero. I suggest a log scale or a break in the scale between 10 and 500. Ordinate also can end at 1000; no N was higher. | Thank you for this recommendation. We have revised the figures accordingly.
4 | p 4 bottom and p 5 top: define “bias” early in the document. You indicate on p 37 that you did not formally assess publication bias, yet you comment on it in multiple places in the document as being low, etc. This seems contradictory. | We have revised the report to clarify that we are reporting the systematic review authors' assessment of the primary studies' risk of bias or publication bias. We assessed the quality of the systematic reviews.
4 | Table ES-1 and Table 2: Iyengar (with a y). | Acknowledged and corrected
4 | Is there a reason that Meyer, et al. J Neuropsychiatr Clin Neurosci. 2012;24:152-164. was not cited? | This publication was identified by our literature search but was excluded at the full-text review stage because we considered it to be a general review, and not a systematic review. We reviewed this again based on the reviewer's comments, and we continue to think that this publication does not meet eligibility criteria for that reason.
5 | There are some on-going trials (see clinicaltrials.gov) that will provide better quality evidence on yoga for chronic back pain and for veterans. These would be important additions to the literature. There is also at least one large trial of yoga for depression ongoing. I think that mentioning these is worthwhile. But, I am unclear about studies of yoga for older adults. These are general trials – at some point, if there is a lot of heterogeneity in the trials, a more careful assessment of the differences in the vigor of the yoga postures would be helpful as that has a clear potential impact on the outcomes. | We appreciate the comment and have now conducted a search of ClinicalTrials.gov to identify studies evaluating yoga that were categorized as ongoing or completed, but for which we could not identify a publication reporting outcomes. We have now reported the results of this search in the report and have added an appendix that lists these studies (Appendix F).
6 | 1. It was stated that there was high bias in the studies looking at yoga for depression and that no tool was used to determine the amount of bias so I am wondering how the determination of bias was made. | We have revised the report to clarify that we assessed the quality of the systematic reviews according to the criteria reported in Appendix D, but that we did not assess bias (or study quality) of the primary studies included in the systematic reviews. The assessment of bias for those studies was conducted and reported by the authors of the systematic reviews.
6 | 2. It was stated that subjects received 10-20 hours of yoga and follow up was done over 5-12 weeks. Am I right to assume that the total amount of yoga was 10-20 hours total as opposed to per week and that the period of intervention and follow up was 5-12 weeks? | Thank you for catching this inconsistency. We have revised the text to clarify that this is total hours of yoga instruction and have calculated a median and range for the time interval of intervention and follow-up.
6 | 3. Exercise was mentioned as one of the controls and I was wondering if it is possible to draw any general conclusions of yoga vs. exercise. The reason I am interested is that when talking about self-care I have suggested that yoga and tai chi could be considered forms of low impact exercise and that it may be reasonable to substitute them in situations where other forms of low impact exercise are used. Having studies that suggest yoga is at least no worse than exercise would be helpful. | In the depression studies, yoga was compared to aerobic exercise in 2 studies, and the decline in depressive symptoms was greater in the yoga groups. Three of the 10 low back pain studies used exercise as a comparator. The report has been revised to reflect these analyses.
6 | 4. Could the types of adverse effects seen with yoga be described? While the patient population doesn't fit the VA it would be nice to know what sort of potential risks are known as this would be important in deciding trial or pilot design. | We have revised the report to add more detailed information about the types of injuries reported and which postures were involved in certain injuries. However, we are limited in what we can provide by the lack of information regarding yoga types and postures in the original case reports and series.
6 | 5. For a paper entitled Evidence Map for Yoga there doesn't appear to be an actual map. The closest thing I see is figure 2. Did I miss something? | We considered a variety of different approaches for summarizing our findings. In so doing, we reviewed other published mapping reports. We found (and concluded) that tables and figures that do not look like maps appear to be the most useful way of summarizing the number, type, and nature of published systematic reviews and RCTs (pending the introduction of more creative and potentially better ways of summarizing and displaying these types of findings).
6 | 6. It is disappointing that there was only one study looking at balance and nothing at falls and that only low back pain and depression had sufficient studies for evaluation. Given the length of time RCTs take it may be prudent for VA to do some demonstration projects and have them set up in a way that the results could be analyzed to hopefully answer some of the questions of efficacy and safety in a VA population. Back pain certainly would seem to be the most promising area based on the findings. The thought of combing modalities such as CBT and yoga is something worth emphasizing more strongly. I'm not sure what to make of the depression studies in terms of what hint it gives to VA as to where to go next. The fact that the meditation component of yoga was part of the evaluation makes me wonder if for this particular condition focusing on meditation and depression for further study may be a better place to start. Hope this helps. I think it gives a lot of food for thought on next steps in terms of how to approach the integration of CAM services and the need to have some demonstration projects/pilots to assess applicability and efficacy in the VA population. | We listed major research gaps along with proposed study designs that could address these gaps. For LBP and depressive disorders, we recommended larger RCTs, or pragmatic comparative effectiveness trials. Demonstration studies would be more appropriate when transferring a proven intervention to new populations, when RCTs are not feasible, or to evaluate the barriers and facilitators to implementing a new intervention. We agree that demonstration projects may be appropriate for LBP studies, and a hybrid type 2 design that evaluates effectiveness and factors related to successful implementation could be particularly useful. We have revised the Discussion to add this.
Optional Dissemination and Implementation Questions
Question 5: Are there any clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | Patient Centered Quality Improvement initiatives. | Acknowledged. Thank you.
2 | I would like to have the report presented at the National Integrative Health Community of Practice Call, held on the second Tuesday of each month at 11:00 ET | We are available to do this on October 14^th^ or December 9^th^.
3 | Yes. This report could inform local VA who have yoga programs where to target recruitment of participants and expected areas for improvement. It will also provide background information for individuals interested in applying for grants studying yoga as treatment. It illustrates areas where more research is needed. | Acknowledged; thank you.
4 | No comments | Acknowledged
5 | I don't know. | Acknowledged
6 | Reviewer gave all comments generally; included under Question 4, above | (See above, under Question 4)
Question 6: Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | This is a very “Academic.” Report. | We have revised the Executive Summary so that it is easier to read and understand.
1 | The bottom line for administrators, clinicians, internal, external VA Stakeholders, and American taxpayers, is should the VA spend money on Yoga treatments to be offered through the VA, or through some type of voucher system? | We appreciate this question, but it is our understanding that we, as authors of this mapping report, are not in a position to make specific recommendations or to attempt to answer policy-related questions.
1 | How does one guarantee the quality of the yoga provided with over 1000 flavors of yoga…? | The information reported by the studies included in our review does not provide information to address this important question.
1 | Who provides the yoga? | We have revised the report by including as much detail about who provided the yoga in each study as was reported by the authors of the systematic reviews.
1 | Given shortages of nurses, doctors and other licensed professionals, national press attention for long wait times, should the VA spend millions of dollars on Yoga, Yoga Research, or more doctors and other licensed clinicians? | Again, we appreciate this very important question, but the ESP does not make specific recommendations on policy-related questions.
1 | Since the people at the VA who make decisions about money and how to spend it, don't have time and thus, are not inclined to read such a dense academic report as this, there should be a one page Reader's Digest version. It should be understandable to people like VA stakeholders as well. | We have revised the Executive Summary (including Table ES-1) so that it is easier to read and understand. In addition, the VA Center for Dissemination and Education will develop an eBrief for widespread dissemination.
1 | The Yoga Industry is like the Drug Company Industry. Having 25 years' experience in clinical trials and working with the pharmaceutical industry, as well as watching the explosion of the Yoga Industry over the past decade, I believe my thoughts are valid. Some medications are good, others, not as good. Some forms of Yoga may be good, others, not so good… Many people in the Yoga Industry would be interested in knowing what “flavor” or “flavors” of yoga they could possibly market to attract customers outside the VA, or contract with the VA to “sell” to new customers. And once the VA decides, who teaches the yoga? Who gets the big Yoga Contract? | We appreciate these comments. We do not think that we are in a position to address these questions in the mapping report. However, our report describes the yoga styles and features of yoga interventions (eg, breathing, postures, meditation) used in trials to date.
1 | Having dealt with the pragmatics of trying to develop yoga programs at the VA, I am deeply aware of the many challenges, such as integrating people who are not licensed clinicians into a medical world. After doing this myself for seven years, I am very much convinced that if yoga is beneficial, and I believe it helps some people, it would be optimal if licensed clinicians could to be trained to provide yoga within the VA. I don't know if this level of pragmatic concern can somehow be transmitted with your report, but millions of dollars are at play here. | We appreciate the importance of this comment and question. Our report includes as much detail as possible (based on what was reported in the systematic reviews) about the training or qualifications of the yoga instructors in the included studies so as to provide information that may help, albeit indirectly, inform policy regarding the potential importance of licensure/training/credentialing of yoga instructors. We have summarized the instructors' qualifications across all studies in the Discussion.
2 | No comment | Acknowledged
3 | Summarize effectiveness findings and place in easy to access table. | We have revised Table ES-1 so that the effectiveness findings are easier to read and understand.
4 | No comments | Acknowledged
5 | I think this is a reasonable summary of the literature, but little data exist to help us understand the value of yoga for veteran populations at this point. | We agree that the lack of studies conducted specifically in Veterans and in samples comprised of generally healthy middle-aged adults limits applicability to Veterans. We now discuss this limitation in the Discussion.
6 | Reviewer gave all comments generally; included under Question 4, above | (See above, under Question 4)
Question 7: Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
1 | Heads of VACO Patient Centered Care Initiatives—these folks are spending millions of dollars on a variety of programs like yoga. Heads of Integrative health and Healing Departments. At Los Angeles, Sandra Robertson, MSN, Kristen Tillisch, MD, Rashmi Mullur, MD I recommend sending your report to NIMH and VA research heads so that it can help direct future research funding initiatives | Acknowledged. Thank you for this recommendation.
2 | I would like to share the report with the new Office of Patient Centered Care and Cultural Transformation's Integrative health Coordinating center. | We think this is a good idea. We will contact the VA ESP Coordinating Center in Portland, OR, to facilitate this.
3 | The Office of Patient Centered Care, the VA Office of Research, National Center for Complementary and Alternative Medicine, the War Related Illness and Injury Study Center (my program), the National Center for PTSD | Acknowledged
4 | No comments | Acknowledged
5 | No comments | Acknowledged
6 | Reviewer gave all comments generally; included under Question 4, above. | (See above, under Question 4)

Abbreviations: CAM=complementary and alternative medicine; CBT=cognitive-behavioral therapy; ES=Executive Summary; ESP=Evidence-based Synthesis Program; LBP=low back pain; MBSR=mindfulness-based stress reduction; NIMH=National Institute of Mental Health; PTSD=posttraumatic stress disorder; RCT(s)=randomized controlled trial(s); VA=Veterans Affairs; VACO=Veterans Affairs Central Office