# Data Abstraction Elements

Study ID
- First author first and last name
- Year of publication
- Ref ID

Objectives
- Stated objectives

Methods
- First search date
- Last search date
- Databases searched
- Language restrictions
- Country restrictions
- Inclusion criteria:
  ○ RCTs
  ○ Observational studies
  ○ Clinical condition(s)
  ○ Yoga intervention(s)
  ○ Comparator(s)
  ○ Outcome timing
- Exclusion criteria
- Primary studies quality rated?
- Comments on methods

Analyses
- Meta-analysis done? (Y/N)
- Meta-analysis software
- Qualitative analysis
- Publication bias assessed?
- Analyses for heterogeneity
- Sensitivity analyses?
- List relevant outcomes
- Comments on analysis

Results
- Total number (#) of included studies
- # of eligible yoga studies
- # of yoga RCTs
- RCT size
- # patients in RCTs
- # of yoga observational studies
- Observational studies size
- # patients in observational studies
- # of other study designs
- # yoga studies from USA
- # primary studies in Veterans
- Patient characteristics
- Outcome timing
- Yoga intervention(s) elements
- Yoga intervention styles
- Yoga intensity
- Outcomes:
  ○ Symptom Severity
  ○ Function/HRQOL
  ○ Adverse effects
  ○ Patient satisfaction
  ○ Resource utilization
  ○ Any effect on cost
  ○ Other
- Quality ratings in studies in systematic review
- Comments on results

Conclusions
- Authors' conclusions
- Comments on conclusions

Other
- Funding source
- Quality rating of SR
- Conflicts of interest
- Limitations
- Other comments