# Search Strategies

## CONDITION-SPECIFIC SEARCHES (BY DATABASE SEARCHED)

Database: PubMed

Search date: 7/30/14

Set # | Depressive Disorders | Results
1 | yoga[mesh] OR yoga[tiab] OR pranayama[tiab] | 2278
2 | “Depressive Disorder”[Mesh] OR “Dysthymic Disorder”[Mesh] OR “Adjustment Disorders”[Mesh] OR “subsyndromal depression”[tiab] OR “subthreshold depression”[tiab] OR “minor depression”[tiab] | 80485
3 | (systematic[sb] OR “Meta-Analysis” [Publication Type] OR “Meta-Analysis as Topic”[Mesh] OR “Review” [Publication Type] OR meta-analysis[tiab] OR search*[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 1778410
4 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 2454824
5 | #1 AND #2 | 37
6 | #5 AND #3 | 9
7 | #5 AND #4 | 21
8 | #5 AND (#3 OR #4) | 27

Set # | Generalized Anxiety Disorder/Panic Disorder | Results
1 | yoga[mesh] OR yoga[tiab] OR pranayama[tiab] | 2278
2 | (generalized anxiety disorder[tiab] OR Anxiety[Mesh:noexp] OR “Anxiety Disorders”[Mesh:noexp] OR “Panic Disorder”[Mesh] OR “anxiety disorder nos”[tiab] OR “mixed anxiety”[tiab] OR panic[mesh])
3 | (systematic[sb] OR “Meta-Analysis” [Publication Type] OR “Meta-Analysis as Topic”[Mesh] OR “Review” [Publication Type] OR meta-analysis[tiab] OR search*[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 1778410
4 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 2454824
5 | #1 AND #2 | 123
6 | #5 AND #3 | 22
7 | #5 AND #4 | 62
8 | #5 AND (#3 OR #4) | 76

Set # | Posttraumatic Stress Disorder | Results
1 | yoga[mesh] OR yoga[tiab] OR pranayama[tiab] | 2278
2 | “Stress Disorders, Traumatic”[Mesh] OR (post[tiab] AND traumatic[tiab] AND stress[tiab] AND disorder[tiab]) OR (post-traumatic[tiab] AND stress[tiab] AND disorder[tiab]) OR ptsd[tiab] | 24834
3 | (systematic[sb] OR “Meta-Analysis” [Publication Type] OR “Meta-Analysis as Topic”[Mesh] OR “Review” [Publication Type] OR meta-analysis[tiab] OR search*[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 1778410
4 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 2454824
5 | #1 AND #2 | 20
6 | #5 AND #3 | 9
7 | #5 AND #4 | 3
8 | #5 AND (#3 OR #4) | 11

Set # | Insomnia | Results
1 | yoga[mesh] OR yoga[tiab] OR pranayama[tiab] | 2278
2 | “Sleep Initiation and Maintenance Disorders”[Mesh] OR insomnia[tiab] OR sleep[tiab] | 107887
3 | (systematic[sb] OR “Meta-Analysis” [Publication Type] OR “Meta-Analysis as Topic”[Mesh] OR “Review” [Publication Type] OR meta-analysis[tiab] OR search*[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 1778410
4 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 2454824
5 | #1 AND #2 | 127
6 | #5 AND #3 | 33
7 | #5 AND #4 | 72
8 | #5 AND (#3 OR #4) | 82

Set # | Low Back Pain | Results
1 | yoga[mesh] OR yoga[tiab] OR pranayama[tiab] | 2278
2 | low back pain[mesh] OR low back pain[tiab] OR lower back pain[tiab] OR lumbago[tiab] OR low backache[tiab] OR low back ache[tiab] OR sciatica[mesh] OR sciatica[tiab]
3 | (systematic[sb] OR “Meta-Analysis” [Publication Type] OR “Meta-Analysis as Topic”[Mesh] OR “Review” [Publication Type] OR meta-analysis[tiab] OR search*[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 1778410
4 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 2454824
5 | #1 AND #2 | 66
6 | #5 AND #3 | 21
7 | #5 AND #4 | 39
8 | #5 AND (#3 OR #4) | 46

Set # | Prevention of Falls | Results
1 | yoga[mesh] OR yoga[tiab] OR pranayama[tiab] | 2278
2 | “Accidental Falls”[Mesh] OR fall[tiab] OR falls[tiab]
3 | (systematic[sb] OR “Meta-Analysis” [Publication Type] OR “Meta-Analysis as Topic”[Mesh] OR “Review” [Publication Type] OR meta-analysis[tiab] OR search*[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 1778410
4 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 2454824
5 | #1 AND #2 | 39
6 | #5 AND #3 | 8
7 | #5 AND #4 | 16
8 | #5 AND (#3 OR #4) | 22

Database: Embase

Search date: 7/30/14

Set # | Depressive Disorders | Results
1 | ‘yoga’/exp OR yoga:ab,ti OR pranayama:ab,ti | 4347
2 | ‘depression’/exp OR ‘adjustment disorder’/exp OR ‘subsyndromal depression’:ab,ti OR ‘subthreshold depression’:ab,ti OR ‘minor depression’:ab,ti | 462905
3 | ([cochrane review]/lim OR [meta analysis]/lim OR ‘meta analysis (topic)’/exp OR [systematic review]/lim OR search*:ab,ti) | 359535
4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random* OR factorial* OR crossover* OR cross NEAR/1 over* OR placebo* OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign* OR allocat* OR volunteer* | 1549715
5 | #1 AND #2 | 617
6 | #5 AND #3 | 98
7 | #5 AND #4 | 249
8 | #5 AND (#3 OR #4) AND [embase]/lim NOT [medline]/lim | 137

Set # | Generalized Anxiety Disorder/Panic Disorder | Results
1 | ‘yoga’/exp OR yoga:ab,ti OR OR pranayama:ab,ti | 4347
2 | ‘generalized anxiety disorder’/exp OR ‘anxiety disorder’/de OR ‘anxiety’/de OR ‘panic’/exp OR ‘generalized anxiety disorder’:ab,ti OR ‘anxiety disorder nos’:ab,ti OR ‘mixed anxiety’:ab,ti | 282704
3 | ([cochrane review]/lim OR [meta analysis]/lim OR ‘meta analysis (topic)’/exp OR [systematic review]/lim OR search*:ab,ti) | 359535
4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random* OR factorial* OR crossover* OR cross NEAR/1 over* OR placebo* OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign* OR allocat* OR volunteer* | 1549715
5 | #1 AND #2 | 644
6 | #5 AND #3 | 86
7 | #5 AND #4 | 240
8 | #5 AND (#3 OR #4) AND [embase]/lim NOT [medline]/lim | 135

Set # | Posttraumatic Stress Disorder | Results
1 | ‘yoga’/exp OR yoga:ab,ti OR OR pranayama:ab,ti | 4347
2 | ‘posttraumatic stress disorder’/exp OR (post:ab,ti AND traumatic:ab,ti AND stress:ab,ti AND disorder:ab,ti) OR (post-traumatic:ab,ti AND stress:ab,ti AND disorder:ab,ti) OR ptsd:ab,ti | 34554
3 | ([cochrane review]/lim OR [meta analysis]/lim OR ‘meta analysis (topic)’/exp OR [systematic review]/lim OR search*:ab,ti) | 359535
4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random* OR factorial* OR crossover* OR cross NEAR/1 over* OR placebo* OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign* OR allocat* OR volunteer* | 1549715
5 | #1 AND #2 | 52
6 | #5 AND #3 | 7
7 | #5 AND #4 | 14
8 | #5 AND (#3 OR #4) AND [embase]/lim NOT [medline]/lim | 10

Set # | Insomnia | Results
1 | ‘yoga’/exp OR yoga:ab,ti OR OR pranayama:ab,ti | 4347
2 | ‘insomnia’/exp OR insomnia:ab,ti OR sleep:ab,ti | 170996
3 | ([cochrane review]/lim OR [meta analysis]/lim OR ‘meta analysis (topic)’/exp OR [systematic review]/lim OR search*:ab,ti) | 359535
4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random* OR factorial* OR crossover* OR cross NEAR/1 over* OR placebo* OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign* OR allocat* OR volunteer* | 1549715
5 | #1 AND #2 | 280
6 | #5 AND #3 | 43
7 | #5 AND #4 | 130
8 | #5 AND (#3 OR #4) AND [embase]/lim NOT [medline]/lim | 66

Set # | Low Back Pain | Results
1 | ‘yoga’/exp OR yoga:ab,ti OR OR pranayama:ab,ti | 4347
2 | ‘low back pain’/exp OR ‘sciatica’/exp OR ‘low back pain’:ab,ti OR ‘lower back pain’:ab,ti OR lumbago:ab,ti OR ‘low backache’:ab,ti OR ‘low back ache’:ab,ti OR sciatica:ab,ti | 44645
3 | ([cochrane review]/lim OR [meta analysis]/lim OR ‘meta analysis (topic)’/exp OR [systematic review]/lim OR search*:ab,ti) | 359535
4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random* OR factorial* OR crossover* OR cross NEAR/1 over* OR placebo* OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign* OR allocat* OR volunteer* | 1549715
5 | #1 AND #2 | 152
6 | #5 AND #3 | 25
7 | #5 AND #4 | 67
8 | #5 AND (#3 OR #4) AND [embase]/lim NOT [medline]/lim | 32

Set # | Prevention of Falls | Results
1 | ‘yoga’/exp OR yoga:ab,ti OR OR pranayama:ab,ti | 4347
2 | ‘falling’/exp OR fall:ab,ti OR falls:ab,ti | 188863
3 | ([cochrane review]/lim OR [meta analysis]/lim OR ‘meta analysis (topic)’/exp OR [systematic review]/lim OR search*:ab,ti) | 359535
4 | ‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random* OR factorial* OR crossover* OR cross NEAR/1 over* OR placebo* OR doubl* NEAR/1 blind* OR singl* NEAR/1 blind* OR assign* OR allocat* OR volunteer* | 1549715
5 | #1 AND #2 | 91
6 | #5 AND #3 | 9
7 | #5 AND #4 | 33
8 | #5 AND (#3 OR #4) AND [embase]/lim NOT [medline]/lim | 19

Database: Cochrane Database of Systematic Reviews

Search date: 7/30/14

Set # | Depressive Disorders | Results
1 | yoga:ab,ti OR pranayama:ab,ti OR MeSH descriptor: [Yoga] explode all trees | 541
2 | MeSH descriptor: [Depressive Disorder] explode all trees OR MeSH descriptor: [Dysthymic Disorder] explode all trees OR MeSH descriptor: [Adjustment Disorders] explode all trees OR “subsyndromal depression”:ab,ti OR “subthreshold depression”:ab,ti OR “minor depression”:ab,ti | 7154
3 | #1 AND #2 | 12
4 | #3: CENTRAL Register of Controlled Trials | 9
5 | #3: Cochrane Database of Systematic Reviews | 0

Set # | Generalized Anxiety Disorder/Panic Disorder | Results
1 | yoga:ab,ti OR pranayama:ab,ti OR MeSH descriptor: [Yoga] explode all trees | 541
2 | generalized anxiety disorder:ab,ti OR “anxiety disorder nos”:ab,ti OR “mixed anxiety”:ab,ti OR MeSH descriptor: [Anxiety] this term only OR MeSH descriptor: [Anxiety Disorders] explode all trees OR MeSH descriptor: [Panic Disorder] explode all trees OR MeSH descriptor: [Panic] explode all trees | 9149
3 | #1 AND #2 | 36
4 | #3: CENTRAL Register of Controlled Trials | 30
5 | #3: Cochrane Database of Systematic Reviews | 3

Set # | Posttraumatic Stress Disorder | Results
1 | yoga:ab,ti OR pranayama:ab,ti OR MeSH descriptor: [Yoga] explode all trees | 541
2 | MeSH descriptor: [Stress Disorders, Traumatic] explode all trees OR (post:ab,ti AND traumatic:ab,ti AND stress:ab,ti AND disorder:ab,ti) OR (post-traumatic:ab,ti AND stress:ab,ti AND disorder:ab,ti) OR ptsd:ab,ti | 1324
3 | #1 AND #2 | 3
4 | #3: CENTRAL Register of Controlled Trials | 3
5 | #3: Cochrane Database of Systematic Reviews | 0

Set # | Insomnia | Results
1 | yoga:ab,ti OR pranayama:ab,ti OR MeSH descriptor: [Yoga] explode all trees | 541
2 | MeSH descriptor: [Sleep Initiation and Maintenance Disorders] explode all trees OR insomnia:ab,ti OR sleep:ab,ti | 11833
3 | #1 AND #2 | 38
4 | #3: CENTRAL Register of Controlled Trials | 34
5 | #3: Cochrane Database of Systematic Reviews | 4

Set # | Low Back Pain | Results
1 | yoga:ab,ti OR pranayama:ab,ti OR MeSH descriptor: [Yoga] explode all trees | 541
2 | MeSH descriptor: [Low Back Pain] explode all trees OR MeSH descriptor: [Sciatica] explode all trees OR low back pain:ab,ti OR lower back pain:ab,ti OR lumbago:ab,ti OR low backache:ab,ti OR low back ache:ab,ti OR sciatica:ab,ti | 4916
3 | #1 AND #2 | 30
4 | #3: CENTRAL Register of Controlled Trials | 19
5 | #3: Cochrane Database of Systematic Reviews | 6

Set # | Prevention of Falls | Results
1 | yoga:ab,ti OR pranayama:ab,ti OR MeSH descriptor: [Yoga] explode all trees | 541
2 | “Accidental Falls”[Mesh] OR fall:ab,ti OR falls:ab,ti | 12672
3 | #1 AND #2 | 16
4 | #3: CENTRAL Register of Controlled Trials | 15
5 | #3: Cochrane Database of Systematic Reviews | 1

## SEARCHES ON ADVERSE EFFECTS OF YOGA

Database: PubMed

Search date: 7/30/14

Set # | Systematic Reviews | Results
1 | yoga[mesh] OR yoga[tiab] OR pranayama[tiab] | 2279
2 | Case reports[publication type] OR case[tiab] OR cases[tiab] OR adverse[tiab] | 3564356
3 | Hematoma[mesh] OR hematoma[tiab] OR purpura[mesh] OR purpura[tiab] OR rupture[mesh] OR rupture[tiab] OR myositis[mesh] OR myositis[tiab] OR lymphocele[mesh] OR lymphocele[tiab] OR occlusion[tiab] OR embolism[mesh] OR embolism[tiab] OR thrombosis[mesh] OR thrombosis[tiab] OR stroke[mesh] OR stroke[tiab] OR psychotic disorders[mesh] OR psychosis[tiab] OR psychotic[tiab] OR pneumothorax[mesh] OR pneumothorax[tiab] OR glaucoma[mesh] OR glaucoma[tiab] OR neuropathy[tiab] OR footdrop[tiab] | 787681
4 | #2 OR #3 | 4072575
5 | #1 AND #4 | 281
6 | #5 AND (systematic[sb] OR “Meta-Analysis” [Publication Type] OR “Meta-Analysis as Topic”[Mesh] OR “Review” [Publication Type] OR meta-analysis[tiab] OR search*[tiab]) | 71
7 | #6, Limits: English, 2008 - present | 45

Set # | Primary Studies | Results
1 | yoga[mesh] OR yoga[tiab] OR pranayama[tiab] | 2279
2 | Case reports[publication type] OR case[tiab] OR cases[tiab] OR adverse[tiab] | 3564356
3 | Hematoma[mesh] OR hematoma[tiab] OR purpura[mesh] OR purpura[tiab] OR rupture[mesh] OR rupture[tiab] OR myositis[mesh] OR myositis[tiab] OR lymphocele[mesh] OR lymphocele[tiab] OR occlusion[tiab] OR embolism[mesh] OR embolism[tiab] OR thrombosis[mesh] OR thrombosis[tiab] OR stroke[mesh] OR stroke[tiab] OR psychotic disorders[mesh] OR psychosis[tiab] OR psychotic[tiab] OR pneumothorax[mesh] OR pneumothorax[tiab] OR glaucoma[mesh] OR glaucoma[tiab] OR neuropathy[tiab] OR footdrop[tiab] | 787681
4 | #2 OR #3 | 4072575
5 | #1 AND #4 | 281
6 | #5, Limits: English, 2011 - present | 112
7 | #6 NOT (systematic[sb] OR “Meta-Analysis” [Publication Type] OR “Meta-Analysis as Topic”[Mesh] OR “Review” [Publication Type] OR meta-analysis[tiab] OR search*[tiab]) (Note – removing duplicates from systematic review search) | 80

## SEARCH OF ALLIED AND COMPLEMENTARY MEDICINE DATABASE (AMED)

Database: AMED

Search date: 7/30/14

Set # | General Yoga Search | Results
1 | (DE “YOGA”) OR TI ( yoga OR pranayama ) OR AB (yoga OR pranayama), Limits: journal article | 195