# SUMMARY AND DISCUSSION

## PREVALENCE

Definitions of events and procedure scope varied in the identified prevalence studies for wrong site surgery. The median prevalence estimate for wrong site surgery was 0.09 events per 10,000 surgical procedures. Two recent surveys showed that 50% of spine surgeons had performed one or more wrong level spine surgical procedures during their career in recent surveys. Lifetime prevalence estimates cover a wide time span and the estimates include the period pre-Universal Protocol so newer estimates may change. A systematic review by DeVine et al.168 identified estimates ranging from 0.09 to 4.5 per 10,000 performed surgical procedures. A 2012 systematic review on errors of level in spinal surgery concluded that the current literature does not provide a definitive estimate of the occurrence of wrong-site spinal surgery.169

Definitions of events and procedure scope varied in the identified prevalence studies for retained surgical items. The median prevalence estimate for retained surgical items was 1.43 events per 10,000 surgical procedures. The most commonly reported item was a surgical sponge. Several studies highlighted that a number of events were discovered even when surgical counts were recorded as correct. The Joint Commission has added the unintended retention of foreign objects to the sentinel event policy in 2005 and reviews between 17 and 188 voluntarily reported events yearly.170

We did not identify any estimates of the prevalence of surgical fires per procedure. One survey showed that 23% of responding otolaryngology and head and neck surgeons had experienced at least one operating room fire in their career, and an analysis of the of the American Society of Anesthesiologists Closed Claims database highlighted that operating room fires accounted for nearly a fifth of monitored anesthesia care claims. Current online fire prevention resource material prepared by the ECRI Institute extrapolated from the 2007 Pennsylvania Patient Safety Reporting system data that the number of fires occurring nationally ranges from 550 to 650.^171^

Comparing prevalence estimates is difficult, in particular, as definitions of the never event of interest varied or, in some cases, were not reported. Studies varied in their differentiation between near misses and event incidents, whether surgical and anesthesia-related care processes were combined in prevalence estimates, and the scope of eligible procedures. We considered different prevalence estimates, such as estimates per procedure or lifetime prevalence per surgeon. Each estimate comes with specific limitations. Most estimates are likely to be an underestimate of the actual occurrence of events, documented is only the frequency of reported events.

## ROOT CAUSES

The identified root cause analyses report a large number of individual causes, risk factors, or contributing factors. A frequently reported cause for wrong site surgery events was communication problems between staff members within or across units. Studies showed how errors resulted from misinformation (e.g., incorrect information obtained from other departments) and misperception (e.g., right-left confusion when interpreting imaging results). A number of studies reported that not following policies, such as time out, not performing safety procedures in a meaningful way (e.g., passive time out), inadequate policies (e.g., site markings not visible after draping), omissions (e.g., laterality was not specified on the consent form), and lack of standardization of procedures contributed to the events.

Given the suspected prevalence, we only identified a small number of root cause analyses for retained surgical items. This may in part be due to the fact that events may not be discovered immediately but instead are identified days or even years later, which may make it more difficult to reconstruct the contributing factors. Case specific, e.g., emergency procedures, or factors related to the surgical environment, with shift changes, incomplete counts, or poor communication, were identified as contributing factors.

Surgical fires were caused by combinations of ignition sources, fuels, and the presence of oxygen. Based on a survey for otolaryngologists, one study identified different fire scenarios and determined that the most common ignition sources were electrosurgical units, lasers, and light cords; common fuels were endotracheal tubes and drapes or towels, and in the large majority of cases, supplemental oxygen was in use. Fire risk increases with procedures involving the face and neck. A recent review concluded surgery will always carry a risk of fire and reducing this risk requires a concerted effort from all team members.172

## GUIDELINES

We identified four guidelines included in the National Guideline Clearinghouse registry, which uses systematic reviews of the evidence to assess the benefits and harms of care options and thus informs optimal patient care. One guideline targeted surgical fires, one on preventing wrong site surgery, one on preventing retained foreign objects, and the fourth covered both wrong site surgery and retained foreign bodies. Two guidelines were specialty specific (interventional radiology and obstetrical) and therefore covered narrow patient populations.

Based on the AGREE II criteria, the overall quality was high for stakeholder involvement and scope and purpose. There was considerable variability for the other domains of guideline development and most had methods problems with regards to transparency and rigor of development. Common themes found across guidelines were the regular use of checklists, importance of standardized communication between the surgical team members, and multiple rechecking throughout the operative process. Specific steps and protocols for preventing wrong site surgery, retained foreign bodies, and surgical fires were outlined in detail for all guidelines.

## INTERVENTIONS

The review identified numerous evaluations of interventions aiming to prevent wrong site surgery, retained surgical items, and surgical fires. However, evaluations lacked replication and most studies had insufficient or no comparators, sample sizes were inadequate, and followup periods were typically short. The evaluations provide some empirical evidence for approaches to prevent wrong site surgery, retained surgical items, and surgical fires; however, apart from global Universal Protocol evaluations, the level of evidence was very low.

Although many publications in the existing literature refer to the need for better communication,173,174 we identified very few empirical evaluations of communication-focused interventions. The wrong site literature repeatedly referred to the importance of all surgical team members needing to feel comfortable to speak up in order to prevent errors and misunderstandings. The retained surgical item literature includes many publications suggesting that counts are documented in full view of the team so that all team members can point out problems. The surgical fire literature refers frequently to the need for surgical teams to discuss the fire hazard of procedures preventatively, this includes communication across disciplines to communicate issues that are not immediately obvious, e.g., it is the responsibility of the anesthesia care team to inform the surgical and nursing personnel about the presence of a high concentration of oxygen in the surgical field; and in the case of a fire, instant, cooperative action is essential.175,176

The included interventions studies show that the implementation success of safety practices varies and those studies reporting compliance show incomplete adherence to the intervention components. In addition, surveys show that although staff may be familiar with the general safety procedure such as Rescue, Activate, Confine, Evacuate (RACE) as suggested by ECRI, a substantial number may not be able to execute the required steps, for example, locating the medical gas supply cut off in order to confine the fire.177,178

The prevention of wrong site surgery was addressed in a substantial number of identified studies. Studies reported on a variety of approaches such as local adaptations and implementations of the Universal Protocol; experiences with preoperative verification, surgical site marking, time out procedures; team training and education; as well as equipment-centered approaches. Several protocol changes used checklists to guide preoperative site verification, surgical site marking, and time out stages. The use of checklists is attributed to the airline industry which acknowledges that humans working in a complex system inevitably make errors when attempting to carry out procedures by memory alone, checklists free up mental capacity, and external prompts may be necessary to improve communication by prompting all team members to speak up.179-182

In recent years, authors have frequently urged to make use of technology such as radiofrequency identification tags to prevent the retention of surgical items.183 One identified study found a statistically significant reduction in event frequency with a data-matrix-coded sponge counting system.61 Cost-effectiveness considerations need to consider the cost of the device as well as medico-legal costs of potentially prevented consequences of incidents. Regenbogen et al.184 concluded from a decision-analytic model comparing no tracking, routine counting, universal x-ray, bar-coded sponges, and two radiofrequency-tagged models that given medical and liability costs exceeding $200,000 per incident, novel technologies can substantially reduce the incidence of retained surgical sponges, at acceptable cost.

The review has identified only a few intervention studies aiming to prevent surgical fires and only one study evaluated a specific approach in more than 200 procedures. Some authors have suggested solutions based on the general principle of eliminating or reducing one of the elements of the fire triangle, most frequently oxygen, either by reducing the concentration185 or by challenging the practice of supplementing with oxygen.186,187 Others have questioned this recommendation and suggested to assess the comparative risks of insufficient oxygen to patients and the risk of surgical fires188,189 hence clinical guidelines need to balance competing factors.190,191 Unique to this surgical never event is that fires can happen very fast, and when they occur, harm to the patient will also occur very fast, resulting in the need for staff to react very quickly in an extreme situation.192 A recent literature review on surgical fires concluded that the risk of fire can be reduced with an awareness of the risk and good communication.172

Conclusive evaluations of interventions to reduce the incidence of wrong site surgery, retained surgical items, or surgical fires are still relatively few in number. Evaluations of interventions aiming to prevent a rare event present a number of challenges in design and interpretation. The most challenging is the limit of inferential statistics. Some studies report reductions in events of 20 to 35% but these are not statistically significant. If an event occurs once in 20,000 occurrences, to have sufficient power to detect a reduction to once in 30,000 occurrences would require a sample of 5,000,000 observations. This is simply beyond the capacity of most interventional studies; therefore, drawing conclusions from evaluations that use traditional methods of inference is problematic when the event is very rare.

Methodological challenges should not mean that empirical evidence for the success of the interventions is not urgently needed. Process measures are only useful if the process is linked to meaningful outcomes.193 The existing literature is saturated with publications suggesting, but not evaluating, approaches that are intended to prevent wrong site surgery, retained surgical items, and surgical fires. Whether the ideas work in practice and are sufficient in preventing sentinel events remains to be shown. Researcher and practitioners may need to consider other methods of evaluation. Examples are the use of adherence to those process measures that have been identified in a root cause analysis as causal or significantly contributing to events in the target organization. In addition, the more frequent “near miss” outcome could be utilized to identify organizational shortcomings and to evaluate interventions.194 Furthermore, the use of run charts or statistical process control may be needed to evaluate the effectiveness of interventions to reduce these rare events. Only one of the included studies reported time to event data.158

## LIMITATIONS

The prevalence data show that all three events are rare. However, the true incidence frequency is not known; this review is limited to the number of reported incidents. The reporting is likely to be influenced by medico-legal considerations which would aim to minimize incidents, while a documented increase in incidents after the implementation of the Universal Protocol has been attributed to an increased awareness.180,195 A further complication is that reporting standards vary widely by institution and are changing over time. We have addressed this issue by including different measures of prevalence including anonymous self reports from surgeons. All methods have inherent advantages and disadvantages. While the self reports should be a better estimate of the true effect given that they are independent from medico-legal considerations, they nonetheless measure recall of incidents, not incidents directly.

We have limited the review to guidelines meeting the criteria of the National Guideline Clearinghouse. This has excluded many tools that are not guidelines as defined for the evidence review but nonetheless are intended to provide guidance to clinicians. Additionally, the quality of the development of the guidelines was variable. Also, the topics and specialties covered were different for each guideline, which made comparisons across guidelines less relevant. In order to advance evidence-based guidelines, new as well as currently published guidelines should follow criteria outlined by the Institute of Medicine.

This report is a summary of the evidence and we have to conclude that the evidence base for the prevention of wrong site surgery, retained surgical items, and surgical fires is still very limited. Nonetheless, the existing literature includes many suggestions that may be tested empirically in future studies or that are suggested by common sense, such as interventions targeting the compliance to the Universal Protocol, the use of fire retardant surgical drapes, or protocols ensuring to let skin preps dry before the patient is draped or before allowing a heat source in proximity.196-205 On the other hand, we have stretched the definition of evidence to include post-only studies given the paucity of the research. A recent Cochrane review on interventions to prevent wrong site surgery and other invasive procedures included only one study (Mahar et al., 2011^206^).

## RECOMMENDATIONS FOR FUTURE RESEARCH

Our evidence report concentrated on the published scientific literature and many of the prevalence estimates involved data cleaning procedures, checking for misclassifications, applying consistent defintions, and establishing how to deal with missing data.181 However, several states have now introduced mandatory reporting of wrong site surgery, retained surgical items, and surgical fires.207-209 A comprehensive review of the regularly published state records would provide a valuable addition to the existing evidence base.

More data are accumulating on a large number of root cause analyses of sentinel events by the Joint Commission accredited hospitals, submitted voluntarily or by the complaint process. This critical information can be used to advance the prevention of wrong site surgery, retained surgical items, and surgical fires. Studies should employ multivariate analyses analyzing multiple, competing potential causes.

Existing prevalence estimates and root cause analyses results vary considerably, factors influencing the variability should be investigated in future analyses. The VA, with its centralized organizational structure, sophisticated electronic health record and databases, and culture of reporting is in an ideal position to address open questions.

Each reviewed content area identified numerous promising practices that have either not been empirically tested in their effectiveness to reduce the outcomes of wrong site surgery, retained surgical items, or surgical fires in practice or studies reported on intermediate outcomes or process measures, such as compliance or acceptance, and were therefore not considered for this evidence review.173,185,210-257 In addition, the existing identified literature is not well suited to draw confident conclusions from reported evaluations, and more empirical evaluations reporting incidents and a denominator such as the number of performed procedures are needed.

However, future studies should not rely on standard statistical tests and evaluations formats given that changes in the frequency in a rare event are investigated. Studies evaluating the adherence to process measures identified in institutional root cause analyses, tracking the more frequent “near misses”, or using run charts and statistical process control would advance the evidence base to determine which interventions can successfully reduce the frequency of wrong site surgery, retained surgical items, and surgical fires.

## CONCLUSIONS

- Wrong site surgery, retained surgical items, and surgical fires are rare events, although estimates of just how rare are imprecise. A rough estimate of incidence is 0.09 for wrong site surgery events and 1.43 for retained surgical items. The goal of these “never events” is zero.
- Root cause analyses have demonstrated a variety of individual causes, however, the most commonly identified factor for all three “never events” was communication between staff members.
- National Guideline Clearinghouse-registered guidelines for preventing wrong site surgery, retained surgical items, or fires are surprisingly few, focused on highly specific applications, and of uneven methodology quality. This paucity of guidelines may be because the Universal Protocol is considered to be “the” guideline.
- Conclusive evaluations of interventions to reduce the incidence of wrong site surgery, retained surgical items, or surgical fires are relatively few in number and present a number of challenges in design and interpretation. The most challenging is the limit of inferential statistics. Some studies report reductions in events of 20 to 35% but these are not statistically significant. If an event occurs once in 20,000 occurrences, to have sufficient power to detect a reduction to once in 30,000 occurrences would require a sample of 5,000,000 observations. This is simply beyond the capacity of most interventional studies, therefore drawing conclusions from evaluations that use traditional methods of inference is problematic when the event is very rare. Other methods of empirical evaluation, such as the use of adherence to process measures identified by institutional root cause analysis, and the use of run charts or statistical process control, may be needed to evaluate the effectiveness of interventions to reduce these rare events.