# RESULTS

The search identified 5,002 publications. Of these, 4,868 were identified in electronic databases. We obtained 1,038 citations as full text publications. The literature flow is shown in Figure 1.

Figure 1 Draft Flow Diagram

## LITERATURE FLOW

In total, 129 studies and guidelines were included in the review. Some studies reported on more than one event (i.e., wrong site surgery, retained surgical item, or surgical fire) or more than one review question (i.e., prevalence, root causes, and/or intervention evaluation).

Three thousand nine hundred fifty-one studies were excluded at the title and abstract stage because two independent reviewers classified them as not relevant to the prevention, root causes, interventions or guidelines for the prevention of wrong site surgery, retained surgical items, or surgical fires. Twelve publications could not be obtained. Three hundred thirty-one publications were classified as background papers and include literature reviews, multiple publications on included studies, and potential future research, and other background material. Two hundred twenty-seven publications were excluded due to the design, e.g. case studies without formal root cause analysis. One hundred nineteen publications were excluded because they did not report on the events of interest (wrong site surgery, retained surgical items, or surgical fires). One hundred eighteen studies were excluded because they did not report on the outcome of interest, e.g. the incident, the prevalence, or the root causes of wrong site surgery, retained surgical items, or surgical fires. Forty-five studies were excluded such as non-US prevalence studies. Twenty-four studies did not report on patients undergoing surgery but were, for example laboratory or technical experiments. Twenty-four studies were identified as duplicates. Seventeen studies were excluded because they reported exclusively on cases of wrong site surgery, retained surgical items, or surgical fires before 2004. Finally, five full text publications were excluded as non-English language publications.

## KEY QUESTION #1 What is the prevalence of: wrong site surgery, retained surgical items, and surgical fires?

We identified US studies in the scientific literature reporting on the prevalence of wrong site surgery, retained surgical items, and/or surgical fires in healthcare organizations. The denominator varied across publications and ranged from event rates per procedure, events reported in a specific time frame, the number of malpractice claims, or self-reported lifetime incidence from surveyed surgeons. To obtain a current estimate of the prevalence of events we only included studies that reported on data obtained in 2004 or after.

### Prevalence of Wrong Site Surgery

We identified 28 studies reporting on the prevalence of wrong site surgery since the introduction of the Universal Protocol. The evidence table summarizes the identified prevalence estimates. The table differentiates general surgery estimates and estimates from specialties and estimates per performed procedure and other denominators.

Table 1 Evidence Table Prevalence Wrong Site Surgery

ID | Type of procedure | Data source/setting | Existing prevention protocol | Denominator | Time frame | Other prevalence (e.g., near miss) | Wrong site surgery events | Prevalence estimates
| Surgery – procedure data
Cima, 2010^29^ | Elective surgery | Institutional event line, academic medical center | Electronic surgical listing system, surgery side and site information are required information | N=55,197 procedures | 2008 | 759/55,197 listing errors (1.38%) including laterality: 66%, incorrect side: 14%, other incorrect listing: 11% | 0/55,197 | n/a
Knight, 2010^30^ | Surgery | Institutional data | Anatomic marking form | N=112,500 procedures | 2004-2008 | n/a | 1 event (skin lesion mistakenly removed and intended lesion missed) | 1/112,500
Kwaan, 2006^31^ | Surgical care | Controlled Risk Insurance Corporation data | n/a | N=2,826,367 operations, 1,153 malpractice claims, 249 surgical care loss observations | 1984-2004 | n/a | 40 cases of wrong site surgery including 25 non-spine events (12 wrong side, 12 wrong site, 1 wrong pt), 15 wrong vertebral level or wrong side spine laminectomy | 1 in 112,994 operations (95% CI: 1/76,336 to 1/174,825)
Mulloy, 2008^32^ | Surgery | Events reported by survey respondents (N=519 CSSTK survey, 325 UPWSS survey) | UP | Procedure data reported by survey respondents | 2001-2006 | n/a | 7,585 events between 7/2004 and 12/2004, 11,607 events in 2005, 7,320 events in 2006 | Rates per 100,000 surgeries: 4.27 in second half of 2004, 3.67 in 2005, 3.14 in 2006
Neily, 2009^33^ | Therapeutic and diagnostic procedures, surgical and invasive procedures | Safety database, VA | Directive “Ensuring Correct Surgery and Invasive Procedures” introduced in 2004, first for OR, then OR and non-OR cases | N=2,028,233 OR procedures | 2001-2006 | 105 OR and non-OR reported near misses (incident in which a recognizable step towards a surgical event occurred without being subjected to a surgical or invasive procedure, e.g., wrong procedure on consent form, eye drops in wrong eye); OR: 91, non-OR: 14 incidents; 1.97 reported close calls per month | 209 OR and non-OR events (unnecessary surgical procedure including incision and punctures); OR: 107, non-OR: 102 events; data from 210 analyzed events in diverse specialties included ophthalmology: 45, invasive radiology: 45, orthopedics: 26, urology: 23, dentistry: 15, general surgery: 13; the specialty data included 56 wrong pt, 65 wrong side, 41 wrong implant, 31 wrong site, 16 wrong procedure, 1 other; 3.21 events per month | Ophthalmology: 0.52 events per 10,000 OR procedures, orthopedics: 1.2/10,000, all other specialties less than 1 event per 10,000 cases
Neily, 2011^34^ | Therapeutic and diagnostic procedures, surgical and invasive procedures | VA | Medical Team Training in addition to “Ensuring Correct Surgery and Invasive Procedures” | n/a | 2006-2009 | 237 OR and non-OR near misses (definition see above; OR: 150, non-OR/Undetermined: 87; 3.24 reports per month | 101 OR and non-OR events (definition see above); OR: 50, non-OR: 51 including ophthalmology: 22, invasive radiology: 22, orthopedics:13; 2.40 reports per month | 0.4 adverse events per 10,000 OR procedures (neurosurgery: 1.56/10,000; ophthalmology: 1.06/10,000)
Wu, 2012^35^ | Surgery | Medical event reporting system, tertiary care academic hospital | n/a | N=17,606 scheduled surgeries | 1-7/2011 | 151 booking errors in 17,606 surgeries | 0/17,606 wrong site events | 0/17,606
| Surgery – other data
Clarke, 2007^36^ | Surgery | Pennsylvania Patient Safety Reporting System | UP | 433,528 reports to safety database | 6/2004-12/2006 | 239 or 253 near misses, 174 wrong surgical interventions started | 83 pts had incorrect procedures done to completion; estimated 1 wrong site event report per year in 300 bed hospital | n/a
Faltz, 2008^37^ | Surgical and invasive procedures | New York Patient Occurrence Reporting and Tracking System (NYPORTS) | n/a | Events reported to NYPORTS during time period | 2003-2005 | n/a | 347 wrong site events reported; surgical procedures including wrong site: 23, wrong side: 27, wrong pt: 2; invasive procedures including wrong site: 21, wrong side: 51, wrong procedure: 68, wrong pt: 33, wrong equipment: 29 | n/a
Griffen, 2007^38^ | Surgery | Claims data for 5 professional liability insurers | UP in place for half of the reporting period | 460 total malpractice claims during time period | 2003-2004 | n/a | 6 wrong patient, organ, or location events | n/a
Mehtsun, 2013^39^ | Surgery | National Practitioner Data Bank | n/a | 9,744 paid malpractice claims with surgical never events | 1990-2010 | n/a | 4,857 events listed as 1^st^ or 2^nd^ allegation on report including wrong site: 2,413, wrong procedure: 2,447, wrong pt: 27; estimate based on database and existing literature: 1,020 wrong procedure surgery events per year in the US, 1,005 wrong site, 33 wrong pt | n/a
Stahel, 2010^40^ | Surgical and nonsurgical procedures | Colorado Physician Insurance company | UP in place for most of the reporting period | Physician self-reported adverse occurrences, 5,937 insured physicians | 1/2002-6/2008 | n/a | 25 wrong pt (14 nonsurgical, 11 surgical), 107 wrong site procedures (29 nonsurgical, 78 surgical) including prostatectomy, vitrectomy, and myringotomy on wrong pts and wrong level spine surgeries, wrong-sided chest tube placement, wrong vascular procedure, enterocolic resection, and organ resection | n/a
| Specialty – procedure data
Adetayo, 2012^41^ | Mastectomy | Chart review, academic medical center | n/a | N=297 pts | 2008-2010 | n/a | 0/297 | n/a
James, 2012^42^ | Hand, arthroscopic, and spine surgery | American Board of Orthopaedic Surgery (ABOS) database | UP mandate introduced during study period; surgeon signed the site preoperatively in 18/20 cases reported after 2007 | N=1,291,396 surgery cases submitted by candidates for board certification | 1999-2010 | Total incidents (wrong site local or regional anesthesia but error was discovered before incision, wrong site skin incision, wrong site surgical exposure, incomplete operation, wrong procedure, wrong side, wrong digit, wrong level of spine; some incidents discovered and corrected during the operation): 71; reported events per year ranged from 1 case in 2003 to 9 cases in 2005 | n/a | Rate of all included incidents was 0.0068%; rate per year ranged from 0.0013 to 0.01; rate post-UPl: 0.0062% (non-spine: 0.0028%)
Jin, 2007^43^ | Cataract surgery | Retrospective review of patients requiring intraocular lens (IOL) exchange at a single eye center | UP introduced at the end of the study period | N=26,667 cataract operations | 1998-2005 | n/a | 3/26,667 wrong intraocular lens implantations | 0.011% of 26,667 cataract operations
Lee, 2007^44^ | Tooth extractions | Institutional risk management database | n/a | N=10,595 tooth extractions | 7/2003-6/2005 | n/a | 5 wrong tooth or wrong site events | 0.047% (5/10,595) per extracted teeth, 0.09% per N of pts
Mody, 2008^45^ | Spine surgery | American Association of Neurologic Surgeons member survey | North American Spine Society “Sign, Mark, and Radiograph,” UP | Lifetime prevalence per surgeon (N=415 of 3,505 members responded); estimated 1,300,000 spine procedures | 2007 survey | 15% of respondents reported that they at least once had prepared the incorrect spine level but noticed the mistake before incision | 50% reported they had performed 1 or more wrong level surgeries during their career | Estimate assuming 418 wrong level spine operations and about 1,300,000 procedures: 1 in 3,110
Shen, 2013^46^ | Strabismus surgery | American Association for Pediatric Ophthalmology and Strabismus member survey | UP, American Academy of Ophthalmology endorsed preoperative checklist available | Lifetime prevalence per surgeon (N=517 of 1,103 members responded); median number of strabismus procedures performed = 1,500 | 2011 survey | n/a | 34% respondents reported having operated on wrong eye or muscle or performed wrong procedure at least once | Mean error rate 1 in 2,506 operations (95% CI: 2,128 to 2,941)
Simon, 2007^47^ | Ophthalmology | Ophthalmic Mutual Insurance company; New York State Health Department database | UP introduced at the end of study period | Claims during time period | 1982-2005 | 14 incidents of wrong eye block | 67 wrong lens implant, 15 wrong eye, 8 wrong pt or procedure, 2 wrong corneal transplants | 7.4 cases of surgical confusion per 100,000 procedures pre-UP, 5/100,000 post-UP
Vachhani, 2013^48^ | Neurosurgery | Institutional Morbidity and Mortality database | UP implemented during study period | N=22,743 surgeries | 1999-2011 | 12 incidents in 7,286 procedures (all wrong level spine surgery) in 5 years pre-UP; 3 incidents in 15,457 procedures (wrong level spine, wrong side cranial surgery) in 7 years post-UP | 2 events of wrong level spine surgery were not identified as an error before the end of the procedure pre-UP, 1 occurred post-UP; 1 wrong side cranial surgery occurred post-UP | All included incidents: 0.07% pre-UP, 0.02% post-UP
| Specialty – other data
Fager, 2006^49^ | Neurological surgery | Malpractice claims | Localizing x-rays | 275 malpractice claims | Up to 2005 | n/a | 16 wrong level lumbar spine, 1 cervical, and 1 thoracic events | n/a
Groff, 2013^50^ | Lumbar spine surgery | American Association of Neurological Surgeons and Congress of Neurological Surgeons member survey | 74% state preoperative x-ray is performed, 56% radiopaque marker inserted through skin, 73% intraoperative x-ray before bone removal | Lifetime prevalence per surgeon (N=569 respondents of 1,045 surveyed) | 2011 survey | 66% of respondents have experienced a close call with wrong level exposed but no bone removal, 3% wrong side exposed but no bone removal, 20% wrong level and wrong side but no bone removal | 50% have performed a lumbar single-level decompression procedure at the wrong level or on the wrong side (33% wrong level once, 14% wrong level > once, 10% wrong side once, 1% wrong side > once) | n/a
Kelly, 2011^51^ | Emergency Medicine procedures | American College of Emergency Physicians Council member survey | UP; 13% unaware of formal time out policy in their ER | Knowledge and lifetime prevalence per surgeon (N=225 respondents of 331 members present) | 2009 survey | n/a | 7% of respondents knew of an ED case wrong site event, 4% of a wrong pt and 1% of a wrong procedure case | n/a
Perlis, 2006^52^ | Mohs Surgery | American College of Mohs Micrographic Surgery member survey | n/a | Lifetime prevalence per surgeon (N=300 of 583 members responded) | 2004 | n/a | 6 respondents had been sued for wrong site surgery | n/a
Schweitzer, 2011^53^ | Foot and ankle surgery | American Academy of Foot and Ankle Surgeons member survey | Some cases occurred after the start of the “Sign Your Site” campaign by AAOS and UP implementation | Lifetime prevalence per surgeon (N=319 of 1,094 members responded) | n/a | 23% of surgeons reported at least once preparing the wrong surgical site but noticed error prior to incision | 13% reported performing at least 1 wrong site surgery, 1% reported 2 wrong site surgeries | n/a
Shah, 2010^54^ | Sinus surgery | American Academy of Otolaryngology-Head and Neck Surgery member survey | More than 50% of cases occurred after the UP implementation | Knowledge and lifetime prevalence per surgeon (N=455 [20%[ responded) | 2009 survey | n/a | 9.3% of respondents have had or heard of a case of wrong site sinus surgery | n/a
Shah, 2011^55^ | Pediatric otolaryngologic surgery | American Society of Pediatric Otolaryngology and CHCA directors survey | UP | Lifetime prevalence per respondent (12 of 43 CHCA and 155 of 254 ASPO members responded [56%]) | 2009 survey | n/a | 21% respondents reported involvement in wrong site surgery at some point in their career | n/a
Wong, 2010^56^ | Orthopedics | American Academy of Orthopedic Surgeons member survey | AAOS “Sign Your Site” and UP | Lifetime prevalence by surgeon (N=917 of 5,540 invited participants of 20,000 members responded) | 2004 survey | 8% of respondents reported a wrong site surgery event or near miss, 2% a pt identification problem | Of 22 analyzed events, 59% involved the wrong side, 23% other wrong location, 14 wrong procedure, 5% wrong pt | n/a

Notes: >: more than; CHCA: Child Health Corp of America Hospitals; CI: confidence interval; ED: emergency department; pt: patient; UP: Universal Protocol

We identified a number of studies reporting on surgery in general, with some studies reporting on wrong site surgery events in the operating room as well as outside the operating room, and varying definitions of wrong site surgery, or no further information on how wrong site surgery was defined in the study. Only a few studies provided sufficient data to allow a rate estimate, i.e., the number of events per performed surgical procedures. The prevalence estimates of wrong site surgery ranged from zero35 to 0.97^34^ events per 10,000 procedures. The median of seven studies providing general surgery estimates was 0.09 events per 10,000 procedures.

A prominent study estimating the prevalence of wrong site surgery was published by Kwaan et al.31 who used an insurance database to arrive at an estimate of 1 event in 112,994 operations (95% confidence interval: 1/76,336 to 1/174,825) from claims data. However, most of the wrong site surgery events must have occurred before the implementation of the Universal Protocol; the estimate is based on data collected between 1985 and 2004. A very similar estimate – one event in 112,500 surgical procedures – was shown by Knight et al.30 reporting on their experiences over 4.5 years with an anatomic marking form as an alternative to the Universal Protocol. Neily et al.33 reported on a large VA dataset and concluded that wrong site surgery events occurred in most specialties in less than one event per 10,000 operations between 2001 and 2006 and the estimate for the wrong site events in operating rooms for the period of 2006 to 2009 was given as 0.4 per 10,000 procedures.34 The studies are reported in more detail in the subgroup section. Two studies reporting on 55,197 elective surgery procedures29 and 17,606 surgical procedures35 found no incidents of wrong site surgery.

Five studies published data reported to safety databases, malpractice claims, or physician self-reported adverse events; all used other denominators than the number of procedures. Clarke et al.36 estimated that given the available data between 2004 and 2006, one wrong site event per year can be expected in a 300-bed hospital. A 2013 study by Mehtsun et al.39 reviewed paid malpractice claims between 1990 and 2010 and estimated, based on identified events and the existing literature, that 1,020 wrong procedure, 1,005 wrong site, and 33 wrong patient surgery events occur per year in the US. One study40 reported that 5,937 insured physicians had reported 11 wrong patient and 78 wrong site surgical procedures to the Colorado Physician Insurance company between 2002 and 2008. A further study37 noted that 347 cases of wrong site events during surgery and invasive procedures were reported to the New York Patient Occurrence Reporting and Tracking System (NYPORTS) between 2003 and 2005. The American College of Surgeon's closed claims study identified 6 wrong patient, organ, or location events in 2003 and 2004^38^, however, the majority of cases must have occurred before the implementation of the Universal Protocol.

The literature search also identified a number of studies reporting wrong site surgery estimates for individual surgery specialties. Estimates varied greatly by specialty and ranged between 0.5 for ophthalmology47 and 4.72 for tooth extractions44 per 10,000 procedures.

Estimates relevant to spine surgery were reported by James et al.42 who reviewed 1,291,396 surgery cases submitted by candidates for board certification by the American Board of Orthopaedic Surgery and determined that the total rate of incidents of wrong site local or regional anesthesia, wrong site skin incision, wrong site surgical exposure, incomplete operation, wrong procedure, wrong side, wrong digit, or wrong level of spine was 0.0068%. The rate varied between 0.0013 and 0.01% between the years 1999 to 2010. Excluding pre-Universal Protocol cases, the rate for hand, arthroscopic, and spine surgery was estimated as 0.0062%; further excluding spine surgery events, the estimate was 0.0028%. A study48 reviewing institutional data for 22,743 neurosurgery procedures estimated that the wrong site surgery prevalence was 0.2% since the introduction of the Universal Protocol. The number included wrong level spine and wrong side cranial surgery cases, regardless of whether the errors were detected and corrected during the operation or completed. Mody et al.45 estimated, based on self-reported lifetime prevalence per surgeon and estimated performed spine procedures, a prevalence of wrong level spine operations in 3110 procedures.

Prevalence estimates for eye surgery were reported by Simon et al. (2007)47,57 who used data from the Ophthalmic Mutual Insurance Company and NYPORTS and estimated there were five cases of surgical confusion (including wrong lens implant, wrong eye, wrong eye block, wrong patient, wrong procedure, or wrong corneal transplants) per 100,000 procedures in 14 months since the implementation of the Universal Protocol. For strabismus surgery, 34% of respondents in a survey for members of the American Association of Pediatric Ophthalmology and Strabismus reported having operated on wrong eye or muscle or performed wrong procedure at least once. The study estimated a mean error rate of 1 in 2,506 operations (95% CI: 2,128 to 2,941) based on the median number of strabismus procedures performed by the surveyed surgeons. An institutional review of cataract operations showed that in 0.01% of procedures a wrong intraocular lens was inserted.43

Prevalence estimates by performance on other specialties were reported by Lee44 who reviewed 10,595 tooth extractions performed between 2003 and 2005 and found a rate of 0.047% of wrong tooth or wrong site events per extracted teeth or 0.09 per number of patients. A small chart review study,41 investigating the frequency of never events such as surgical site infections and catheter-related urinary tract infections in breast reconstruction, found no wrong site surgery incidents in 297 patients.

Other identified prevalence data came from surveys, usually asking about lifetime prevalence per surgeon. The surveys showed the large variation in estimates across specialties, in particular spine surgery compared to other specialties. In a 2011 survey elicited by the Joint Section on Disorders of the Spine and Peripheral Nerves (Spine Section), half the respondents reported that they have performed a lumbar single-level decompression procedure at the wrong level or on the wrong side.50 Similarly, the survey by Mody et al.45 showed that 50% of respondents in a survey for members of the American Association of Neurologic Surgeons reported that they had performed one or more wrong level surgical procedures during their career.

Other survey data showed that of the members of the American Academy of Orthopedic Surgeons only 8% of survey respondents reported a wrong site surgery event or near miss.56 Thirteen percent of foot and ankle surgeons reported to have performed at least one wrong site surgery and one percent reported two.53 Twenty-one percent of respondents reported involvement in wrong site surgery at some point in their career performing pediatric otolaryngologic surgery in a 2011 survey.55

Three identified studies reported on other outcomes: six respondents of 300 members of the American College of Mohs Micrographic Surgery had been sued for wrong site surgery.52 Seven percent of the American College of Emergency Physicians Council member survey respondents knew of an emergency department wrong site case, 4% of a wrong patient, and 1% of a wrong procedure case.51 Finally, in a survey for members of the American Academy of Otolaryngology Head and Neck Surgery, 9% of respondents have had or heard of a case of wrong site sinus surgery.

Several prevalence studies highlighted which interventions and policies aiming to prevent wrong site surgery were in place at the time the prevalence estimate was obtained. For the majority of studies, the Universal Protocol had been in effect for some or all of the observation period, in addition, specialty endorsed campaigns such as “Sign Your Site” or preoperative checklists endorsed by the American Academy of Ophthalmology46,54 were available.

#### VA Subgroup Analysis: Prevalence of Wrong Site Surgery

We identified two studies reporting on large VA setting datasets. Neily et al. (2009)33 reported the prevalence of incorrect surgical procedures within and outside of the operating room between 2001 and 2006. In this study, adverse events were defined as incidents in which the patient had undergone a surgical procedure unnecessarily and the definition included all injections and administration of regional or general anesthetic not needed for the planned procedure. The specialty orthopedics (1.2 events per 10,000 cases) was second to ophthalmology (1.8 events per 10,000 cases) for the number of reported adverse events occurring in the operating room. None of the other specialties had more than one event per 10,000 cases. In a subsequent article in 2011, Neily et al.34 reported on data obtained in 2006 to 2009 and estimated that 0.4 adverse events occurred per 10,000 operating room procedures. Estimates for neurosurgery alone were 1.56 per 10,000 cases and 1.06 per 10,000 cases for ophthalmology.

### Prevalence of Retained Surgical Items

We identified 20 journal publications reporting on the prevalence of retained surgical items. Studies varied how they defined events and near misses, e.g., whether items identified before wound closure would be classified as an event or near miss incident. The evidence table summarizes the identified studies, differentiating general surgery estimates and data from surgical specialties. We extracted the type of retained item where reported. In the evidence table we have reserved the retained surgical item event column for incidents of unintentionally retained items that were only discovered postoperatively. The prevalence estimate only includes unintentionally and not discovered items at the time of the procedure and is limited to the number of operations as the denominator.

Table 2 Evidence Table Prevalence Retained Surgical Items

ID | Type of procedure | Data source/setting | Existing prevention protocol | Denominator | Time frame | Other prevalence outcomes | Retained surgical item events | Prevalence estimate
| Surgery – procedure data
Camp, 2010^58^ | Pediatric surgical procedures | National Inpatient Sample and Kid's Inpatient Database | UP in place during last portion of study period | N =1,946,831 hospitalizations | 1988-2005 | n/a | 413 patients with retained foreign body left during a procedure | 0.18 per 1,000 pediatric surgical pt discharges; 0.97 for transplant, 0.96 for gynecologic, and 0.75 for vascular
Chen, 2011^59^ | Surgical and medical procedures | Use of AHRQ PSI 5 (Foreign body left during procedure) to flag events in VA inpatient administrative data and electronic medical record data | 19/23 surgical procedures had documentation of correct surgical counts, 4 with disagreements | N=2,342,690 discharges, 28 of 158 acute-care hospitals | 10/2002-10/2007 | 42 foreign body events and near misses; 23 related to surgical procedures including sponge/gauze: 12; instrument/device fragments: 7; discovered during original procedure: 9/23; site reopened before leaving OR: 2, in 7 cases surgeon decided to remove later; 19 medical procedure events and near misses including 13 guidewires or fragments (53% related to device malfunction), 11/19 detected at time of procedure | 14 surgical foreign bodies discovered postoperatively; 8 medical procedure foreign bodies not discovered at time of procedure | n/a (rate of true and false positives = 0.14 per 1,000 cases in sample and 0.12/1,000 cases across all VA hospitals)
Cima, 2007^60^ | Events in main ORs and labor and delivery unit | Incidents reported to sentinel phone line or website in academic medical center | 21/34 events with correct counts recorded; in 18 cases, intraoperative x-rays were obtained which identified 12 items | N=191,168 operations | 2003-2006 | n/a | 34 retained foreign object events (item unintentionally retained and discovered after wound closure or when the pt had left the OR) including 23 sponges, 3 needles, 1 instrument, and 7 others items | 0.178 per 1,000 operations (1:5,500)
Cima, 2011^61^ | Surgery | Single academic medical center | UP, sponge counting protocol | 87,404 procedures | 2/2009-7/2010 | 3 manual miscounts caught by electronic system | 0 retained sponges in 87,404 procedures with new system | 0/87,404
Egorova, 2008^62^ | Surgery | Medical Event Reporting System, Total HealthSystem, administrative hospital, and NY State Cardiac Surgery report databases | Counts of instruments and supplies (study only reviewed count discrepancies) | N=153,263 surgeries | 2000-2004 | 17 near misses and events with incorrect counts; 11 items were removed prior to closure | 5 events without count discrepancy but item subsequently discovered (1 yr followup); 6 events with count discrepancy (1 yr followup) | 1:7,000 surgeries (0.014%)
Greenberg, 2008;^63^ Greenberg, 2008^64^ | Elective general surgery | Medical center data | 2004 AORN protocol for counting instruments and sponges or bar coding surgical sponges | N=298 operations | n/a | n/a | 0/148 retained items and 0/150 in other intervention | n/a
Hunter, 2010^65^ | Surgery | Academic medical center data | X-ray protocol | N=appr. 11,374 surgeries (1,034 per month) | 8/2008-7/2009 | n/a | 2 sentinel cases of retained foreign items in 11 months | 2/11,374
McIntyre, 2010^66^ | Surgery | Medical center data | Routine surgical postoperative x-rays for abdominal, thoracic, spinal, and gynecological procedures, sponge counting before and after incision and closure; new count and x-ray policy introduced during study period | About 12,000 surgical procedures per year | n/a | n/a | 3 events in 2 years before protocol introduction, 0 events in 18 months after | 3/24,000 pre, 0/18,000 post protocol implementation
Rupp, 2012^67^ | Surgery | Academic health system data | Sponge ACCOUNTing System, later radiofrequency detection system implemented | n/a | Before and after 2006 | n/a | 0 retained items in 2,285 pts after radiofrequency intervention, 1 retained surgical item per 36,000 operations before ACCOUNTing System, 1/54,000 operations after | 1/36,000 after second intervention, 1/54,000 before
Stawicki, 2012^68^ | Any surgery | Data from 7 teaching institutions | In 55/59 cases surgical counts performed; 13 of 27 cases had imaging performed but the item was missed on initial x-ray interpretation; radiofrequency tagging systems were in place in 2 cases where items were missed | N=411,526 cases | 1/2003-12/2009 | Additional 3 items recorded but not analyzed (incomplete data) | 59 unintentionally retained surgical items identified within a pt after final skin or fascial closure of the wound, including 30 surgical sponges, 5 non-sponge textiles (towel, cottonoid, packing), 12 metallic items (needle, wire, drill/screw), 11 non-metallic items (drain/tubing, polyurethane/cement) | Retained surgical item rate: 1/6,975
Vannucci, 2012^69^ | Intraoperative CVC placement | Academic medical center | Root cause analysis after first 2 cases, mandatory training for new interns, CVC checklist, training module for residents | Procedures performed in 6 years | n/a | n/a | 4 retained guidewires | 1:3,291 (95% CI: 1/10,000 to 8/10,000)
| Surgery – other data
Griffen, 2007^38^ | Surgery | Claims data for 5 professional liability insurers | n/a | 460 total malpractice claims closed in 2003 and 2004 | 2003-2004 | n/a | 20 retained foreign bodies | n/a
Lincourt, 2007^70^ | Surgical procedures | Medical records and reports from institutional Risk Management; academic medical center | In 4 events, incorrect counts were followed by inadequate x-rays (item outside the x-ray field) | n/a | 1996-2005 | n/a | 30 unintentional retained foreign body events, including 3 ray-tec sponges, 13 lap pads, 13 instruments, 1 basket from broken device | n/a
Mehtsun, 2013^39^ | Surgery | National Physician Data Bank, paid malpractice settlements | n/a | 9,744 paid malpractice claims with surgical never events | 1990-2010 | n/a | 4,857 events of a surgical retained foreign body listed as 1^st^ or 2^nd^ allegation on report; estimate based on database and existing literature: 2,024 retained foreign body incidents per year in the US | n/a
Samples, 2004^71^ | Surgical procedures | VA National Center for Patient Safety SPOT database | n/a | Events during time period | 2000-2004 | 29 close calls of retained sponges | 41 adverse events involving retained sponges (peanut sponge, gauze pads, laparotomy pads, surgical towels, folded surgical drapes) | n/a
| Specialty – procedure data
Adetayo, 2012^41^ | Mastectomy | Chart review, academic medical center | n/a | N=297 pts | 2008-2010 | n/a | 0/297 | n/a
Lutgendorf, 2011^72^ | Vaginal deliveries | Labor and delivery unit data | Vaginal sweep; count and x-ray protocol implemented during study period | N=10,500 deliveries (post) | appr. 2005-2011 | n/a | 4 retained sponges with vaginal sweep, 0 events after protocol implementation | Rate 1/5,000 deliveries before intervention, 0/10,500 after
Morse, 2010^73^ | Bowel surgery | Retrospective analysis of elderly pt in single academic medical center | n/a | 151 pts | 1/2008-3/2009 | n/a | 0/151 foreign body retained after surgery | 0/151
Teixeira, 2007^74^ | Cavitary trauma surgery | Academic trauma center data | Weekly morbidity and mortality conference; sponge and instrument counts | N=10,053 trauma operations | 1998-2005 | n/a | 3 iatrogenic retained foreign body events, all after laparotomy, all surgical sponges | Rate 0.1% (3/10,053 operations); expected incidence of 0.12% for cavitary surgery and 0.14% for laparotomies
| Specialty – other data
Simonsen, 2010^75^ | Tonsillectomy and adenoidectomy | Malpractice claims from 16 medical liability insurance companies | n/a | 154 claims filed or closed between 1985 and 2006 | 1985-2006 | n/a | 3 retained foreign bodies including 1 retained nasopharyngeal packing, 1 broken suture needle | n/a

Note: AORN: Association of PeriOperative Registered Nurses; CVC: central venous catheter; pt: patient; OR: operating room; yr: year

Eleven studies reported prevalence data of unintentionally retained items in unspecific surgical and medical procedures. Prevalence estimates varied widely and ranged between zero retained sponges61 and 3.04 retained guidewire69 events per 10,000 surgical procedures. The median estimate across nine studies was 1.43 in 10,000 procedures. The most commonly reported item was a surgical sponge.

Four authors reported per-procedure data for individual surgical specialties, i.e., bowel surgery, breast reconstruction, vaginal deliveries, and cavitary trauma surgery.41,73,74 The bowel and the breast reconstruction surgery studies presented zero events but reported on less than 300 patients. A study reporting on experiences with a new prevention protocol for vaginal deliveries showed zero events in 10,500 deliveries but noted that previously, sponges were forgotten at a rate of 1 in 5,000 deliveries despite the practice of vaginal sweeps. A study by Teixeira et al.36 analyzing a large time frame ranging from 1998 to 2005 reported a rate of 0.1% of retained items in cavitary trauma surgery; in all instances this was a surgical sponge.

It is noteworthy that several studies highlighted that the events occurred despite the existing precautions. Ten studies explicitly reported that the hospitals had a counting protocol and two studies highlighted that imaging did not identify all items: Cima et al.44 reported that 21/34 events occurred in operations where the counts were recorded as correct and of 18 included cases, intraoperative x-rays were obtained but the x-ray only identified 12 of the items. Similarly, Lincourt70 reported that in four events incorrect counts were followed by inadequate x-rays because the item was outside the x-ray field.

#### VA Subgroup Analysis: Prevalence of Retained Surgical Items

We identified one VA setting study reporting a per-procedure estimate. Chen et al. (2011)59 investigated the validity of the patient safety indicator “Foreign body left during procedure” and followed up incidents reported between 2003 and 2007. The study identified 42 instances of events and near misses associated with surgical or medical procedures observed over 28 hospitals with 2,342,690 recorded discharges. In total 14 surgical foreign bodies were discovered postoperatively and eight events occurred in medical procedures and were not discovered at the time of the procedure. A 2004 analysis of the VA National Center for Patient Safety SPOT database identified 29 close calls and 41 cases of adverse events involving retained sponges.71 The sponges were discovered before and after wound closure or were found when searches were initiated due to incorrect sponge counts; however in some cases, retained sponges were detected days, weeks or years later when x-rays were taken for symptomatic patients during routine x-rays, or during autopsies.

### Prevalence of Surgical Fires

The literature review identified no study reporting a per-procedure estimate of surgical fires. None of the included US intervention studies reported on the prevalence. The included prevalence studies are summarized in the evidence table.

Table 3 Evidence Table Prevalence Surgical Fires

ID | Type of procedure | Data source/setting | Existing prevention protocol | Denominator | Time frame | Fire events | Prevalence estimate
Metzner, 2011^76,77^ | Surgical procedures requiring anesthesia | American Society of Anesthesiologists Closed Claims Project database | n/a | 5,230 claims | 1985-2007 | 91 cautery burns or fires since 1990; 27 cautery fires and at least 1 death due to airway fire during laser surgery by 2004 | n/a
Simonsen, 2010^75^ | Tonsillectomy and adenoidectomy | Malpractice claims from 16 medical liability insurance companies | n/a | 154 claims filed or closed between 1985 and 2006 | 1985-2006 | 2 airway fires (1.3%) | n/a
Smith, 2011^78^ | Otolaryngology and head and neck surgery | American Academy of Otolaryngology-Head and Neck Surgery member survey (N=349 out of 2300 members responded) | n/a | Lifetime prevalence by respondents | n/a | 23% of responding surgeons had experienced at least 1 OR fire in their career; 10 had experienced 2 fires; 2 reported 5 fires | n/a

Note: OR: operating room

The survey among members of the American Academy of Otolaryngology-Head and Neck Surgery showed that a quarter of responding surgeons had experienced at least one operating room fire in their career. A review of 154 malpractice claims from 16 medical liability insurance companies between 1985 and 2006 identified two airway fires.75 Metzner et al.76 reported 91 closed claims due to cautery burns or fires in the American Society of Anesthesiologists Closed Claims Project database since 1990. The publication highlighted that operating room fires account for nearly a fifth of monitored anesthesia care claims. A previous analysis in 2004^77^ reported 27 cautery fires at that time and at least one death caused by an airway fire during laser vaporization of tracheal stenosis.

Prevalence estimates, i.e., the rate per surgical procedure was not reported in the literature.

#### VA Subgroup Analysis: Prevalence of Surgical Fires

We did not identify any VA setting study reporting on the prevalence of surgical fires.

## KEY QUESTION #2 What are the identified root causes of: wrong site surgery, retained surgical items, and surgical fires?

The results of the root cause, risk factor, and contributing factor analyses are documented by event.

### Root Causes of Wrong Site Surgery

We identified 23 analyses investigating wrong site surgery events. The evidence table summarizes the identified studies, ordered by the number of investigated incidents. We only included studies reporting exclusively or at least in part on time periods with the Universal Protocol had been in effect. We have broadly structured the causes and risk factors by operating room provider behavior, patient or case related factors, equipment factors, and other factors.

Table 4 Evidence Table Root Causes Wrong Site Surgery

ID | Country, setting/surgery | Event | N events | Assessment context, format | Existing prevention protocol | Provider behavior risk factors/causes (N) | Pt/case risk factors/causes (N) | Equipment risk factors/causes (N) | Other factors
Clarke, 2007;^36^ Clarke, 2008^79^ | US, general surgery | Wrong site surgery (wrong pt, procedure, side, or part) near misses | 427 | Reviewed hospital and ambulatory surgical center reports | UP | Actions of surgeon (92), action of anesthesia provider (29), errors in positioning pt and preparing site (20), not verifying site markings (16), problems with marking the site (6), failure of formal time out process (59) | Incorrect info from pts (17), most event involved symmetrical anatomic structures | n/a | Scheduling errors (111), office records not available (4); causes summarized as resulting from misinformation or misperception
Mody, 2008^45^ | US, spine surgery | Wrong site surgery | 418 | Survey data, provider characteristics and reported events correlated | “Sign, Mark, and Radiograph”, UP | Higher rate of wrong level surgery seen with increased age of surgeon (p=0.024) | n/a | | No association with annual surgical load, no difference between surgeons in academic or private practice
Neily, 2009^33^ | US, VA, therapeutic and diagnostic, surgical and invasive procedures | OR and non-OR reported near misses and events | 342 | Root cause analysis | VA Directives for OR, then OR and non-OR introduced during study period | Ranked by frequency: communication problems (e.g., informed consent issues, problematic communication of critical info/handoffs with missing info), time out problems (e.g., pt not properly identified), non-standardization/other, human factor problems, OR schedule problems, training/education, other root causes, problems with policy, documentation, staffing problems, time pressure | n/a | n/a | n/a
Faltz, 2008^37^ | US, general surgery | Wrong pt, wrong side, wrong site procedures | 254 | Root cause analyses submitted to NYPORTS | New York State's 2001 Pre-Operative Protocol, UP | Communication failure, team issues, noncompliance with procedures, inadequate training, consent issues, incomplete history and pt information, failure to correlate available information, inadequate pre-procedural verification, site marking issues, inadequate time-out | Inadequate pt identification | Room set-up issues | Inadequately designed procedures, lack of compliance monitoring, production/time pressures, complete info not available (e.g., lab report), inaccurate/incomplete scheduling info
Neily, 2011^34^ | US, VA, therapeutic and diagnostic, surgical and invasive procedures | OR and non-OR reported near misses and events | 237 | Root cause analysis | VA Directive for OR, and non-OR | Human factors or structural problems (17), critical information not communicated (14), training/education - general (9), pt info not obtained/ accessed (9), no time out (9), policies not followed (7), documentation problematic (6), communication problems – general (6), pt not properly identified in time out (5), implant not verified in time out (5), staff distracted (5), problems with informed consent (4), time out problems - general (3), site not verified in time out (3), site not marked in time out (3), consent not properly checked in time out (3), radiologic images not properly reviewed in time out (3), time pressure (3), training and education for physicians (2), staffing problems – inappropriate use of staff (2), short staffed (2), Directive not followed (1), time out not done in meaningful way (1), site not marked correctly in time out (1), fatigue (1) | Pts had same last name (12), pt characteristics a problem – e.g., dementia (3) | n/a | Critical clinical processes not standardized (36), root cause indiscernible/un-codeable (13), other root causes – general (10), policy needs improvement (4), lack of policy (2)
Shen, 2013^46^ | US, Strabismus surgery | Wrong procedures, wrong muscles, wrong eyes, wrong pts, miscellaneous | 173 | Survey data, self-reported events and causes | UP, American Academy of Ophthalmology endorsed preoperative checklist available | Contributing factors: esotropia/exotropia/recession/resection confusion (34), hypertropia/hypotropia confusion (12), inattention or distraction (19), following preset pattern (9), Kerstenbaum-Anderson confusion (3), wrong preoperative plan (5), no time out (7), lack of site marking/incorrect draping (4), wrong medical record consulted (2), change in schedule/new order (1), new assistant (3) | Ocular torsion (20), scarring/reoperation/bleeding (8), similar pt names (2), sequential pts with similar deviation (1) | n/a | n/a
Kelly, 2011^80^ | UK, multiple settings and surgeries | Wrong intraocular lens (IOL) implants | 164 | NRLS database search, submitted principle reason extracted | n/a | Inaccurate biometry (29), wrong IOL selection (21), transcription error (10), handwriting misinterpretation (7), change in list order (8), right/left eye confusion (4), wrong IOL written on theatre white board, wrong pt notes (2), communication errors (2) | Pt ID issue (4), wrong IOL power implantation after complicated surgery (3) | n/a | Optimal IOL power unavailable in stock (3), no causal reason documented (62), misfiled biometry (4)
Stahel, 2010^40^ | US, general surgery | Wrong pt, wrong site procedures | 132 | Root cause analyses | UP | Misinterpreted test results (18), failure to diagnose or misdiagnosis (14), delayed diagnosis (6), failure to perform test (3), other diagnosis error (4), unnecessary treatment (110), medication error (6), delayed treatment (12), wrong treatment concept (3), failure to treat (8), other treatment issues (4), written communication error (33), verbal communication error (26), handover info error (10), other communication issue (51) inadequate procedure planning (92), guideline violation (2), no time out (77) | Wrong indication for procedure (1) | Technical treatment error (21), environmental safety or security issue (1) | Other system issues (24)
Simon, 2007;^57^ Simon 2007^47^ | US, ophthalmology | Surgical confusions (wrong implant, transplant, eye, eye block, pt, or procedure | 106 | Ophthalmic Mutual Insurance company; NY State Health Department database | UP introduced at the end of study period | Surgeon alone responsible (35), surgeon and others responsible (58), staff but not surgeon responsible (6) | n/a | n/a | Unknown responsibility (7)
Blanco, 2009^81^ | US, general surgery | Wrong site occurrences and near misses | 97 | Analyzed reports using the Pennsylvania Safety Authority Wrong site Surgery Error Analysis Form | UP, Pennsylvania Safety Authority Checklist Error analysis form available online | n/a | Existence of bilateral pathology significantly more common among actual events than near misses | Non-standard setup of OR or surgical equipment sign. more common among events than near misses | n/a
Cohen, 2010^82^ | Canada, craniotomy | Wrong site craniotomy | 35 | Literature database search, Google News, disciplinary actions and survey from state medical licensing boards, court records from civil lawsuits | n/a | Contributing factors to ≥2004 cases: assuming prepped side is correct side (1), surgeon ignored team member questioning laterality (1), failure to notify resident that operating on wrong side (1), failure to mark incision site (2), failure to complete/follow time out (4), side not indicated on consent form (2), failure to check medical records (1), failure to fill out necessary document before procedure (1), reliance on memory (1), surgeon accepted full responsibility (1), laterality mix-up in medical record (1) | Contributing factors to ≥2004 cases: pts with same first name (1) | Contributing factors to ≥2004 cases: physician moved OR table (1), non-conventional MRI scanning (1) | Summarized as communication breakdown, inadequate preoperative checks, technical factors and imaging, human error
Shah, 2010^54^ | US, sinus surgery | Wrong sinus or wrong sided endoscopic sinus event | 21 | Survey data, self-reported example events | n/a | n/a | n/a | Radiographic error with inverted image (10)
Kwaan, 2006^31^ | US, non-spine surgery | Wrong site surgery | 13 | Case review | n/a | Clinic note or consent form with incorrect note (1), site or side not specified in consent form (6/9) | | Incorrectly printed magnetic resonance image (1) | Errors in OR scheduling (4), multiple lesions not identified/documented in clinic visit (3), radiologic findings not available (2/4)
Mallett, 2012^83^ | US, surgery and medical procedures | Wrong site, procedure, and pt; surgical and non-surgical events | 8 | Root cause analysis using VA Triggering and Triage Cards | UP | Rules, policies and procedures (22), human factors – scheduling, fatigue (7), human factors – communication (8), human factors – training (3), barriers (6) | n/a | Environment and equipment (3) | Frequent failure modes: 1. Procedure consent form w/out needed detail/not obtained, 2. Lack of workflow standardization/responsibilities and flow of information, unaware that documents have to be reconciled and who is responsible for pre-procedure verification
Mitchell, 2006^84^ | UK, neurosurgery | Wrong side surgery | 8 | Surgeon interviews | Varied | Site not marked (6), incorrect marking (1), pt positioned incorrectly by assistant (1) | Multiple simultaneous operations on same pt (1) | Difficulty accessing imaging results (1) | Outside distraction during positioning (7), replacement surgeon as scheduled surgeon could not be found (1)
Schein, 2012^85^ | US, eye surgery | Wrong intraocular lens (IOL) implants | 7 | Identified cases resulting from a formal review or root cause analysis | UP, AO recommendations | No verification of intended IOL (1), handwriting misinterpretation (1), misread +/- IOL (1) | Wrong patient IOL calculation printout (2) | Measurement form changed (1), similar lens model name (1) | n/a
Duthie, 2010^86^ | US, operative and non-operative settings | Wrong pt Venous Doppler Ultrasound, wrong sided needle localization, wrong site radiation procedure, wrong site CT scan, wrong sided surgical procedure | 5 | Examined cases from a large urban academic medical center | n/a | Ineffective check (2), reliance on verbal processes (2), site not specified (1), lack of safety checks (1), lack of checklist with critical repeat backs (1), interruptions (1), passive time-out procedures (1) | Pt identification issue (1) | Manual overrides (1) | Summarized as cognitive underspecification, cognitive flips, automode processing, skill-based errors
Neily, 2012^87^ | US, VA, eye surgery | Wrong eye implant, incorrect nerve block, wrong site excision of lesion, wrong site excisional biopsy | 4+ | Root cause analyses | UP | Multiple pt lens or paperwork in the OR (1), site marking confusion (2+) | Biopsy site confusion with pts with scars or lesions (1) | Change in clockface orientation tool during surgical handoff (1) | n/a
Jin, 2007^43^ | US, cataract surgery | Wrong IOL implants | 3 | Review of pts requiring IOL exchange | n/a | Inattention of technicians or nurses passing along the wrong lens during surgery (3) | n/a | n/a | n/a
No author, 2008^88^ | US | Wrong site surgery | 1 | Health Care Quality staff interviews | UP | Failure to notice site marking, failure to conduct a time-out | Uncommon surgical procedure | n/a | n/a
Knight, 2010^30^ | US, skin lesion removal | Wrong site surgery | 1 | JC required institutional event analysis | Anatomic marking form | Pt not marked | Elderly and confused pt | n/a | n/a
Knight, 2006^89^ | US, interventional radiology | Wrong site surgery | 1 | Root cause analysis | UP | Failure to mark procedural site, lack of time-out for verification check | n/a | Crowded, noisy control room, images orientation not matching pt orientation | n/a
Lee, 2010^90^ | US, inguinal hernia surgery | Wrong side surgery | 1 | Root cause analysis | Extended Time Out | Inadequate marking (not visible after draping) | Pt also had left inguinal hernia (right side was scheduled) | n/a | n/a

Note: The number in parentheses shows the number of causes unless specified differently (number of times the variable was considered a contributing factor); AO: Academy of Ophthalmology; ID: identification; JC: Joint Commission; N: number; NRLS: UK National Reporting and Learning System maintained by the National Patient Safety Agency for National Health Service providers; n/a: not reported/not available; NYPORTS: New York Patient Occurrence Reporting and Tracking System; OR: operating room; pt: patient; pts: patients; UP: Universal Protocol; w/out: without

We have identified a number of studies investigating the causes of wrong site surgery events through reviewing large institutional or insurance or state databases. We searched the international literature; however, the evidence table only shows studies in settings that are largely comparable to the VA. Most studies are US-based, data from the UK and Canada are also included.

The evidence table documents a large number of individual causes, risk factors, or contributing factors. The studies vary how much detail is known or reported about each event, some analyses reported only on broader categories after reviewing individual events, and some studies organizing structures to analyze the surgical mistakes such as VA Triggering and Triage Cards.83

While some causes appear unique to the specific surgical field, e.g., implanting a lens model with a similar name during eye surgery,85 others appear not specific to surgery, e.g., problems created by not communicating critical information between team members,45 consulting the wrong medical record,46 transcription errors80 or distractions.84

Some reasons were frequently identified as contributing to a number of analyzed wrong site surgery events within a dataset and are also reported very frequently across different studies. In terms of provider behavior, a frequently reported cause or contributing factor was communication problems between staff members within or across units.33,34,80,82,83 This included missing information that should have been available to the operating room staff, omitting critical information, staff members not speaking up although they noticed that the procedure targeted the wrong side, as well as lawsuits showing that a surgeon ignored team members questioning laterality. Clarke et al.79 summarized a review of 174 wrong site errors affecting a patient and 253 errors not directly affecting a patient reported to the Pennsylvania Patient Safety Reporting System that wrong site errors result from misinformation or from misperception. Misinformation may result from information obtained in other departments; misperception may result for example from right-left confusions.

In terms of patient or case characteristics a number of studies highlighted that patient identification problems were common, including the unfortunate circumstance that similar or identical first or last names or even similar clinical conditions were the cause of the wrong site surgery.34,37,46,80,82,86 Incorrect information from patients or families and confused patients were also named as a contributing factor why the error was not detected.30,34,36 In addition, some surgical procedures always involve symmetrical structures where laterality is a major concern.36,80

A few studies reported equipment-related issues such as the room set up, including moving the operating room table, recently changed forms with information in different places, or forms lacking crucial information such as the laterality of the planned procedure.37,40,81-83,85,87,89 Some studies highlighted that error was introduced when imaging results were misinterpreted because the patient orientation was confused, such as non-conventional MRI scans with feet first rather than head first.54,82,89

A large number of studies identified policies as the source of wrong site surgery. This concerned either the failure of staff to follow existing policies, technically correct but practically useless policies, or the lack of policies. A number of studies reported that not following standard procedures, such as the lack of site marking or not performing time out, was the cause or a contributing factor to the investigated cases of wrong site surgery.30,33,34,36,37,40,46,82,85,86,88,89 For these cases it was typically pointed out that the organizational procedure was in place, but it was not followed by staff. Other studies showed that a procedure was technically followed but it was practically inadequate because the surgical site had been marked but the mark was not visible after draping or time out was not performed in a meaningful way.34,86,90 Finally, several studies, including large datasets investigating several hundred cases of wrong site surgery reported that the lack of procedures or standardization of procedures caused wrong site surgery events.34,37,83 An institutional review of wrong site surgery cases by Mallett et al.,83 for example, concluded that frequent failure modes were 1) The procedure consent form did not contain needed detail, such as the laterality of the procedure, or the consent form was not obtained by the practitioner; and 2) A lack of workflow standardization, with staff not realizing that various documents had to be reconciled against one another, and no clearly identified responsibility to determine pre-procedure preparation.

Finally, several root cause analyses showed that mistakes or changes early on in the process, such as errors or changes in scheduling, mistakes on clinic paperwork or consent forms, and incorrect draping, are likely to be carried forward and result in wrong site surgery without further safety checks in place.31,36,46,84,91 Clarke et al.79 outline how misperception can result from right-left confusion, for example with unconventional patient positions, and combined with conformation bias, i.e., a tendency to confirm the earlier mental impression regardless of the physical facts, cause wrong site errors.

#### VA Subgroup Analysis: Root Causes of Wrong Site Surgery

We identified three studies reporting on VA-specific data. Neily et al. (2009)33 analyzed root cause analysis reports between 2001 and 2006 and concluded that communication problems were the most frequently reported cause of wrong site therapeutic and diagnostic procedures (21%), closely followed by time out problems (18%). A followup report analyzing 2006 to 2009 reports34 concluded that the category Critical Clinical Processes Not Standardized was the most frequent root cause (18%). The category described situations in which a clinical process was left to the judgment of the clinician to accomplish. The second most common cause category was termed Human Factors or Structural Problems (8%). This category described problems with the human-machine interface, look-alike packaging of different implant components, and other problems with the environment or time pressures, distraction, or fatigue.

Finally, Neily et al. (2012)87 reported on an evaluation for “shared lessons learned” to prevent incorrect surgery by using examples reported to the reporting system for adverse events through the National Center for Patient Safety. The selected examples describe specific and concrete situations that occurred regardless of the Directive “Ensuring Correct Surgery and Invasive Procedures” and involved the availability of multiple lenses in the operating room leading to confusion, ophthalmologist and anesthesia misinterpreting the meaning of the site mark, a biopsy site confusion attributed to multiple scars and lesions, or a case involving a surgical team taking over from the initial team, with both surgical teams using a clock face orientation tool but with a 180 degree discrepancy in how it was placed.

### Root Causes of Retained Surgical Items

We identified only a small number of risk factor analyses in the international literature reporting on retained surgical items. Other studies reported the results of formal institutional root cause analysis for individual cases evaluated in their organization (between one and three investigated cases).

The evidence table summarizes the identified root causes, contributing factors, and risk factors. All 18 included studies reported exclusively or at least in parts, on recent cases which happened in the last decade despite existing policies and available technology. The table is ordered by the number of investigated events.

Table 5 Evidence Table Root Causes Retained Surgical Items

ID | Country, setting/surgery | Event | N events | Assessment context, format | Existing prevention protocol | Provider behavior risk factors/causes (N) | Pt/case risk factors/causes (N) | Equipment risk factors/causes (N) | Other factors
Camp, 2010 58 | US, National Inpatient Database and Kid's Inpatient Database | Retained foreign body by Pediatric Quality Indicator code | 413 | Case-control study with multivariable regression analysis | n/a | n/a | Statistically significant higher odds of retained foreign bodies in gynecology procedures (OR 4.13) | n/a | n/a
Wan, 2009^92^ | International, multiple settings and surgery | Gossypiboma/retained sponges | 254 | Literature review to 6/2008; primary author reported risk factors | n/a | Shift changes (9), incomplete count (absent or interrupted; 8), poor communication (e.g., hierarchy and lack of cooperation; 5), no clear standardized count policy (3) | Emergency procedure (6), lengthy procedure (6), unexpected change in procedure (3), multi-cavity cases (>1 surgical field/procedure; 3), high BMI (4) | Use of non-radiopaque sponges (7) | n/a
Stawicki, 2012^68^ | US, surgery | Retained surgical items | 59 | Retrospective, multi-center case-control study 2003-2009; multivariate analysis | 55/59: surgical counts; at least 13: imaging, 2 with radiofrequency tagging system | Safety omission/variance: OR 10.7 (95% CI 2.98, 38.9, p<0.001) | BMI: OR 1.11 (95% CI 1.02, 1.2, p=0.019); procedure duration: OR 1.41 (95% CI 1.03, 1.92, p=0.006) | n/a | Unexpected intraoperative events: OR 6.97 (95% CI: 2.04, 23.7, p<0.001)
Chen, 2011^59^ | US, VA, Surgical and medical procedures | Foreign body left during procedure | 42 | Administrative data and electronic medical record | Counts | n/a | BMI ≥30 (surgery: 35%) | Related to device failure or malfunction (surgery: 30%, medical procedures: 53%) | n/a
Samples, 2004^71^ | US, VA, Surgical procedures | Retained sponges | 41 events, 29 close calls | VA National Center for Patient Safety SPOT database | AORN recommendations | Counts not recorded; suboptimal communication in surgical team; lack of clarity in x-ray requests leads to incomplete interpretation by radiologist; attending physicians not familiar with AORN standards | Changes or complications in surgical procedures | Radiopaque sponge not used consistently; music and conversation contribute to lapse in concentration; stressful OR environment with people coming and going and multiple hand-offs of responsibility; inability to obtain stat X-ray reading from radiology department hinders validation of incorrect count | Incorrect counts are common; local policy differs from AORN; productivity pressure; inconsistent policies for incorrect counts or missing sponge is not visible on x-ray leaves staff without direction; count audits focus on documentation not process; surgeons role in count not clearly defined
Cima, 2007^60^ | US, main OR and labor and delivery unit | Item unintentionally retained and discovered after wound closure or when the pt had left the OR | 34 | Root cause analyses | 21/34 events with correct counts recorded; some intraoperative x-rays | Failure of communication among OR team members most frequent contributor to event | No event occurred during emergency operation; only 41% had excessive blood loss (majority did not) | n/a | No unplanned changes in operations; 41% events in operations performed after hours
Lincourt, 2006^70^ | US, Surgical procedures | Unintentional foreign object remaining in the body (sponges, instruments) | 30 pts | Case-control study 1996-2005; multivariate analysis | Counts performed in most cases | Incorrect counts (RR 16.2, 95% CI: 1.3-197.8, p=0.02) predicts event | n/a | n/a | Total number of major procedures performed (RR 1.6, 95% CI: 1.1, 2.3, p=0.008) predicts event
Healy, 2012^93^ | Ireland, obstetrics | Retained vaginal swabs | 16 | Closed claim analysis | n/a | Practitioner error (16); no documentation regarding swab count (8); lack of staff knowledge, skills, and competency in procedure for perineal suturing (16) | n/a | n/a | Workload issues, interruption or task delegated due to emergency (4)
Moffatt-Bruce, 2012^94^ | US, endovascular procedures; multicenter | Retained intravascular items; intravascular: guide wire, catheter/ catheter fragment, coil | 13 cases with intravascular items; 83 other cases | Multicenter retrospective case-control study over 6 year period | 7/13 items were missed on initial confirmatory post-procedural imaging | n/a | Technically difficult procedures (6), difficult/emergent setting (2) | Equipment failures (5), lack of equipment familiarity (2) | n/a
Modrzejewski, 2011^95^ | International, multiple settings and surgery | Migrated foreign body from peritoneal cavity into colon | 10 | Literature review | n/a | Circumstances may have been caused by hurried activity of surgical staff | Hemorrhaging during surgery reported in 3 cases and 2 cases with caesarean section | n/a | n/a
Whang, 2009^96^ | US, single academic medical center | Retained foreign body | 7 | Root cause analysis | Surgeon-dependent intraoperative surveillance radiography | Suspicion not communicated to radiologist (5), x-ray never read by radiologist (1), x-ray results not communicated to care team (1) | Inadequate image quality due to pt obesity (1), | Poor image quality (1), item outside of radiograph's field of view (1) | n/a
Gibbs, 2011^97^ | US, minimally invasive surgery | Retained surgical items in minimally invasive surgery | 4+ | Incident reports, focused reviews, root cause analyses | n/a | Sponges counted but intraoperative location not accounted for by OR personnel, no transparent system for accounting of instruments and other surgical items; communication between radiologists, radiology techs, and surgeons when performing surveys for retained items | n/a | n/a | Summary: events occur because of problems with multi-stakeholder OR practices and problems in communication
Vannucci, 2012^69^ | US, academic medical center | Retained guidewires | 4 | Root cause analysis | Mandatory training for new interns after first 2 cases | Inadequate supervision by attending provider (4), inexperienced resident performing the procedure (2), medical student involvement (1) | Concurrent transesophageal echocardiogram (3), unstable hemodynamics (2) | Multiple open venous access kits (4), double access procedure requiring multiple guidewires on surgical field (2) | n/a
McIntyre, 2010^66^ | US, surgical procedures | Retained laparotomy sponges | 3 | Root cause analyses | Routine x-rays for selected procedures, sponge count | n/a | Obese pt and image off center, should have received 2 films to cover abdomen, firm read by resident not surgeon (1); no sponge count due to emergent operation and tail of sponge only visible at edge of x-ray (1) | n/a | Inconsistency in documenting and accounting for packs intentionally left, no policy for obtaining post-operative x-ray (1)
Teixeira, 2007^74^ | US, Cavitary trauma surgery | Surgical sponges left behind | 3 | Institutional records | Weekly morbidity and mortality conference; sponge and instrument counts | n/a | Emergent case with risk factor requiring damage control (2) | n/a | n/a
Hunter, 2010^65^ | US, surgery | Sentinel events of retained foreign objects | 2 | Institutional records | Counts | Miscommunication – radiologist told nurse there was an item visible, nurse reported to surgeon that no foreign item was seen (1) | n/a | n/a | Counts were correct so no radiographs taken (1)
Agrawal, 2012^98^ | US, obstetrics | Retained vaginal sponge after repair of vaginal tear during delivery | 1 | Root cause analysis | Standard counting protocol of sponges before and after procedure | Failure to perform standard counting protocol; information management and communication: breakdown of teamwork among physician and nurse, hierarchical boundaries, culture of poor communication; human resources/people: addition of newborn, failed human memory, busy clinical environment | n/a | n/a | Policy or procedure: lack of reminders to perform count, recent implementation of policy
Connelly, 2011^99^ | US, orthopedics | Retained plastic pulsatile lavage irrigator tip | 1 | Root cause analysis | n/a | n/a | n/a | Nozzle tip not included in count; off label modification of pulse irrigator tip | n/a

Note: AORN: Association of periOperative Registered Nurses; BMI: body mass index; N: number; n/a: not reported/not available

Included studies analyzed the published cases or their own institutional data. Some studies only reviewed specific cases such as retained intravascular items and migrated items from peritoneal cavity into the colon, or cases specific to selected surgery, such as minimally invasive surgery or obstetrics.

Camp et al. (2010)58 determined in a multivariate regression analysis that among pediatric surgical admissions, a foreign body left during a procedure occurred with the highest likelihood during gynecologic operations.58 A study published by Wan et al.92 reviewing 254 cases of gossypiboma reported that risk factors were case specific, for example emergency procedures, or related to the surgical environment with shift changes, incomplete counts, or poor communication. A recent multivariate analysis by Stawicki et al.68 also reported that the occurrence of any safety variance such as incorrect counts at any time during the surgical procedure was associated with an elevated retained surgical item risk. The analysis showed further that body mass index, unexpected intraoperative events, and procedure duration were also independently associated with an increased risk. A second multivariate analysis published by Lincourt et al.70 reported that incorrect counts and the total number of performed major procedures were statistically significantly predictive of the risk of retained foreign bodies after surgery.

In terms of provider behavior, several studies reported safety omissions such as incomplete or not documented counts as a contributing factor.68,70,92,93,97,98 Communication shortcomings were also frequently reported.60,65,92,97,98 A series of root cause analyses determined that in five out of seven cases the lack of communicating suspicions, such as inaccurate sponge count not communicated to the radiologist, was a core problem.96 Cima et al.60 concluded after reviewing institutional root cause analyses that failure of communication among operating room team members was the most frequent contributor to events.

Case related factors, such as emergency or technically difficult procedures, were determined to be causal or contributing factors in a number of studies.68,74,92,94 However, Cima et al.60 reviewing 34 events pointed out that none occurred during an emergency operation. Furthermore, while 41% of cases showed evidence of excessive blood loss, the authors pointed out that most patients did not. The patients' Body Mass Index was a significant predictor in the multivariate analysis of 59 cases reported by Stawicki68, contributed to four cases reported by Wan et al.,92 and one institutional root cause analysis speculated that using an additional x-ray in order to cover the entire abdomen of an obese patient may have been warranted.66

The analysis of the international published case studies by Wan et al.92 suggested that the use of non-radiopaque sponges was responsible or contributed to 7 cases. A study reporting on foreign bodies left during surgical and medical procedures in VA settings concluded that approximately 40% of events were related to a device failure or malfunction, in particular in medical procedures.59 Similarly, a study by Moffatt-Bruce investigating retained intravascular items showed that equipment failures and lack of equipment familiarity was a factor in almost half of the analyzed cases.94

Unexpected intraoperative events was a significant predictor of events in the Stawicki et al.68 analysis. However, the analysis by Cima et al.60 pointed out that there were no unplanned changes in operations in any of the 34 cases of unintentionally retained items. An Irish study analyzing 16 retained vaginal swabs reported that a quarter was associated with workload issues and interruptions.

Several studies pointed to problems with policies, in particular the institutional root cause analyses. One study stated that although the technology is available to staff, the lack of a policy when to obtain post-operative x-rays contributed to one case of a retained laparotomy sponge.66 It should be noted that several studies reported that a count policy was in place but it was either not standardized, or otherwise ineffective, or items were retained (e.g., broken off nozzle tip) that were not counted.92,97,99

The more detailed institutional root cause analyses showed also that typically more than one factor contributed to an event. An analysis of the root causes of a retained vaginal sponge after repair of a vaginal tear following normal vaginal delivery showed that the fundamental error in the case was the failure to perform the standard protocol of counting sponges before and after the procedure.98 Factors that contributed to the error and the resulting adverse event were the lack of visual reminders to perform the recently implemented policy, a breakdown of teamwork among physician and nurse, hierarchical boundaries, a culture of poor communication, the addition of a newborn baby, failed human memory, and a busy clinical environment.

#### VA Subgroup Analysis: Root Causes of Retained Surgical Items

Two VA setting studies reported root causes of retained surgical items. Chen et al. (2011)59 investigating incidents reported between 2003 and 2007 showed that 30% of surgical and 53% of medical foreign bodies were related to a device failure or malfunction. This included instruments breaking off during the procedures and device fragments accidentally being left in the patient. An analysis of retained sponge incidents recorded in the NCPS SPOT database by Samples and Dunn71 identified a large number of contributing factors, including inconsistent policies and practices when sponge counts are incorrect, or when a missing sponge is not visualized on x-rays, which leaves staff without clear direction (in particular as incorrect sponge counts are commonplace and usually not associated with an actual retained sponge). However, the analysis took place in 2004 suggesting that most analyzed cases occurred before the implementation of current standards.

### Root Causes of Surgical Fires

We identified 15 root cause analyses reviewing published fire incidents, survey data, and individual fire incidence formally investigated in an organization. The evidence table, ordered by the number of analyzed fire incidents, summarizes the studies.

Table 6 Evidence Table Root Causes Surgical Fires

ID | Country, setting/surgery | Event | N events | Assessment context, format | Existing prevention protocol | Provider behavior risk factors/causes (N) | Pt/case risk factors/causes (N) | Equipment risk factors/causes (N) | Other factors
Smith, 2011^78^ | US, otolaryngology | OR fires | 100 | Survey data American Academy of Otolaryngology-Head and Neck Surgery members | n/a | n/a | Endoscopic airway surgery (27), oropharyngeal surgery (24), cutaneous/transcutaneous surgery (23), tracheostomy (18) | Monopolar electrosurgical ignition source (59), laser source (32), light cord melted drapes source (7), bipolar electrosurgical unit (1), anesthesia machine source (1); 81% of fires occurred while supplemental oxygen was in use, common fuels included endotracheal tube (31%), OR drapes/towels (18%) and flash fires (11%) | n/a
Richter, 2008^100^ | International, pharyngeal surgery, tonsillectomy, tracheostomy | Electrosurgery related fires including endotracheal tube fires and flash fires | 31+ | Literature review, staff interview in single tertiary pediatric institution | n/a | n/a | n/a | Endotracheal tube leak with high oxygen concentration (7), high oxygen concentration during trachea incision (23), dry gauze pack Sevoflurane concentration (1); high concentrations of anesthetic gas and oxygen that accumulated due to lack of cuffed endotracheal tube or pharyngeal packing; eschar debris on electrode blade associated with flash | n/a
Metzner, 2011^76,77^ | US, Surgical procedures requiring anesthesia | Cautery burns or fires, laser airway fires | 27+ | American Society of Anesthesiologists Closed Claims Project database | n/a | n/a | Most cautery fire burns occurred on the face or in the airway | Use of supplemental oxygen most often listed as inciting event; alcohol-based preparation solution cited in some cases | n/a
Pierce, 2011^101^ | US, surgery | Laser-induced fires | 16 | Industry-compiled Laser Accident Database | n/a | n/a | High oxygen environment due to facial surgery (2), endotracheal tube ignition during laser surgery (7) | Ignition of surgical drapes during laser surgery (2), ignition of laser device itself (4) | n/a
Rocos, 2012^102^ | UK, NHS providers | Fires in the OR | 13 | Fires reported to NRLS between 2004 and 2011, causes extracted | n/a | Misuse of equipment causing ignition (2) | n/a | Presence of flammable skin prep fluid (chlorhexidene, povidone-iodine)/prep soaked swabs and drapes (11) | n/a
Haith, 2012^103^ | US, burn center | OR fire injuries | 5 | Institutional review and case report | n/a | n/a | Risk increases with procedures involving the face and neck (e.g. tracheostomy and tracheobronchial surgery) | Ignition sources include electrocautery, lasers, faulty OR equipment; common use of oxygen/nitrous oxide mixtures or enriched oxygen for minimally complex procedures and disposable drapes add to the risk (fuel source and drapes trap gas); use of electrocautery near an oxygen/nitrous oxide mixture source resulted in injuries | n/a
No author, 2008^104^ | US (2), Netherlands (1) | Surgical boom fires | 3 | ECRI investigation and literature review | n/a | n/a | n/a | Loose oxygen hose fitting within equipment manager box (2), electrical short (2), worn oxygen hose (1), dust collected in electrical outlet (1) | n/a
Meltzer, 2005^105^ | US, pediatric hospital, neurosurgery | Surgical fire | 3 | Multidisciplinary systems-based analysis to identify causal factor for 1 case, literature review | n/a | n/a | Pt's excessive amount of hairspray combined with staff failing to allow the prep solution to dry completely prior to draping (1) | Electrocautery use in oxygen-rich environment in the presence of alcohol based prep solution (1), combination of alcohol-based surgical prep solution and use of monopolar electrocoagulator (1) | n/a
No author, 2006^106^ | US, surgery | Surgical fires and near-misses | 2 fires, 1 near miss | Case reports | Institutional fire prevention policy (1) | Surgeon refused to allow water to be cleaned up (1), staff unfamiliar with equipment (1); Mayo stand placed on electrocautery foot pedal (1) | n/a | Multiple providers entering and leaving room (1); water pooling on floor near exposed electrical plug (1); packing material containing alcohol, staff unaware (1) | n/a
Kaddoum, 2006^107^ | US, adenotonsillectomy | Flash fire in oropharynx during in children | 2 | Case reports | n/a | n/a | | Leak around endotracheal tubes raised oxygen concentration in oropharynx combined with electrocautery (2) | n/a
Laudanski, 2010^108^ | US, anesthesia | Anesthesia machine fires | 2 | Case analysis with series of experiments | n/a | n/a | n/a | Moisture wick in breathing circuit caught on fire due to crossed wires (2) | n/a
Beesley, 2006^109^ | UK, emergency laparotomy | Surgical fire | 1 | Reflective account using Gibbs' reflective cycle | n/a | Started surgery before prep was dry using pencil diathermy rather than scalpel; saline not readily available | Emergent bowel perforation repair | n/a | Smoke detector did not go off
Cady, 2007^110^ | US, cyst removal | OR fire | 1 | Legal deposition | n/a | Wrong oxygen concentration | Anesthesia difficult (obese pt, high blood pressure, claustrophobia) | Supplemental oxygen | n/a
Herman, 2009^111^ | US, organ procurement | Surgical fire | 1 | Root cause analysis | Annual fire education within organization (some team members from outside hospital) | Lack of awareness of role in preventing fires (technician had no control over flammable liquids, surgeon left alcohol-soaked gauze sponge on pt and placed electrocautery device in close proximity), lack of communication between OR team members (anesthesiologist observed surgeon place gauze around tracheostomy and presumed it was soaked in saline), no water readily available to extinguish flames | n/a | Alcohol moistened sponges combined with electrocautery | n/a
Lypson, 2005^112^ | US, facial surgery | Surgical fire | 1 | Organizational review involving chief of staff, chief of surgery, chief of anesthesiology, and safety case management committee | n/a | n/a | n/a | High likelihood of a draping problem resulting in oxygen being trapped and subsequently igniting when the cautery unit was used | n/a

Note: NRLS: UK National Reporting and Learning System maintained by the National Patient Safety Agency for National Health Service providers; n/a: not reported/not available; OR: operating room

The majority of included root cause analyses did not identify a single cause but described combinations of factors that contributed to an operating room fire. Most details were reported by Smith et al.78 who structured the contributing factors by type of otolaryngology surgery and listed the ignition source, the fuel, and the presence of oxygen, describing several different fire scenarios. The data were obtained by sending a questionnaire to otolaryngologists and the 349 respondents described 100 fires they had experienced in clinical practice. The authors summarized that the most common ignition sources were electrosurgical units, lasers, and light cords. The described fires occurred most often during endoscopic airway surgery, followed by oropharyngeal surgery, cutaneous or transcutaneous surgery of the head and neck, and during tracheostomy. Over eighty percent of fires occurred while supplemental oxygen was in use. In terms of fuels, commonly involved substances were endotracheal tubes and operating room drapes or towels, but flash fires, where no substrate burned, were also common.

Only a few studies highlighted explicitly problematic provider behavior such as misuse of equipment causing an ignition102 or starting the surgery before the preparation solution was dry and not having saline readily available for cases of fire109 but several, primarily, equipment- related causes could also be attributed to staff behavior, such as using electrocautery near an oxygen nitrous oxide mixture source.103,106 Results of a formal root cause analysis of a single fire occurring in an organization showed that lack of awareness of the roles in preventing fires was apparent, starting from a scrub technician without control over flammable liquids to a surgeon leaving an alcohol-soaked gauze sponge on the patient and later placing an electrocautery device in close proximity to this known fuel source.111 Furthermore, communication problems were also attributed the event, with the anesthesiologist observing the surgeon placing the gauze around the tracheostomy and mistakenly presuming that it was soaked in saline rather than alcohol.

With regard to case-related factors, Haith et al.103 investigating victims of operating room fires in a burn center concluded that risk increases with procedures involving the face and neck such as tracheostomy and tracheobronchial surgery. An analysis of the American Society of Anesthesiologists Closed Claims Project database76 highlighted that claims associated with fire almost always occurred in the setting of surgery on the head, face, and neck.

As outlined, Smith et al.78 described several ignition sources such as monopolar electrosurgical ignition sources and lasers specific to surgery, while other risks such as faulty equipment, light cords, or crossed wires were also reported.78,103,104,108 Other authors highlighted endotracheal tube leaks or draping problems which raised the oxygen concentration and trapped oxygen;100,112 several authors pointed out the risks of supplemental oxygen.76,78,103,110

A review of fires reported in the NHS between 2004 and 2011 showed that 11 out of 13 fires were attributed to the presence of flammable skin preparations113 and in particular alcohol-based preparation solutions were also cited in other studies as a major cause of surgical fires.105,109,111 However, the analysis of 100 otolaryngology fires explicitly mentioned that alcohol-based preparation solution was among the group of less common fuels.78

#### VA Subgroup Analysis: Root Causes of Surgical Fires

We did not identify any studies reporting on root causes of surgical fires specifically in a VA setting.

## KEY QUESTION #3 What is the quality of current guidelines in use to prevent wrong site surgery, retained surgical items, and surgical fires?

The National Guideline Clearinghouse staff identified four guidelines relevant to our three topics areas of wrong site surgery, retained surgical items, and surgical fires. Supplemental Google searches in September 2013 did not identify additional documents meeting the Institute of Medicine definition of a guideline. The four guidelines were: 1) Quality Improvement guidelines for preventing wrong site procedure and wrong person errors: application of the Joint commission “Universal Protocol for presenting wrong site, wrong procedure, wrong person surgery” to the practice of interventional radiology by Society of Interventional Radiology (SIR) 2009,^114^ 2) Prevention of unintentionally retained foreign objects during vaginal deliveries by Institute for Clinical Systems Improvement (ICSI) 2012,^115^ 3) Perioperative protocol. Healthcare protocol by ICSI 2012,^116^ and 4) Practice Advisory for the Prevention and Management of Operating Room Fires by the American Society of Anesthesiologists Task Force on operating room fires 2013.^117^ Three of the four guidelines were on focused primarily on the target topics. However, the guideline on applying the Universal Protocol to the specialty of interventional radiology also included minimizing wound infection rates for surgical patients. For this guideline, references and recommendations on wound infection were not reviewed or discussed. Details of the objectives, target population, outcomes, and major recommendations are listed in Table 7.

Table 7 Evidence Table Guidelines for the Prevention of Wrong Site Surgery or Other Invasive Procedures, Retained Items in Surgery and Other Invasive Procedures, and the Prevention of Surgical Fires

Guideline title | Guideline objective | Target population | Major outcome | Description of methods | Methods to formulate recommendations | Major Recommendations: Limited to wrong site surgery, retained foreign bodies and OR fires
Prevention of unintentionally retained foreign objects during vaginal deliveries. Health care protocol115 | To describe the necessary steps, which if implemented, should prevent unintentional retention of foreign objects during vaginal delivery. | Patients who present with an anticipated vaginal delivery. | Eliminate rate or number of unintentional foreign bodies left following vaginal delivery. | Literature search of clinical trials, meta-analyses, systematic reviews, or regulatory statements and other professional order sets and protocols. Search terms for the current revision include retained foreign objects and labor and deliver from May 2009 through June 2011. | Expert Consensus | Clinical Highlights Sponges/soft goods, sharps, and miscellaneous items will be counted for vaginal deliveries. Sponges/soft goods with radiopaque markers are only soft goods present in the delivery field. Establish accurate count processes for baseline and final counts. If the baseline count is not accurately performed before using any countable items, all subsequent controls should be considered compromised. For compromised and reconciled counts, a radiograph shall be obtained to ensure that a foreign object has not been unintentionally retained.
Perioperative protocol. Health care protocol*116 | To eliminate the wrong surgical procedure or surgery performed on the wrong body part or on the wrong patient. To eliminate unintentionally retained foreign objects during a surgical procedure. To improve the adherence to the key components of the Perioperative Protocol. | Adult and pediatric patients undergoing a surgical procedure in a hospital inpatient, outpatient, or freestanding surgical center. | Effectiveness of surgical site marking, Time-Out, and Hard Stop for prevention of wrong surgical procedure, wrong site, or wrong patient. Effectiveness of baseline count, radiologic imaging, and operating/procedure room survey for prevention of retaining of foreign objects. | Literature search was divided into two stages to identify systematic reviews (stage I) and randomized controlled trials, meta-analyses, and other literature (stage II). Search was from November 2009 through 2012 included terms: Medicare never events, quality, new fires in operating room, patients awake/anesthesia awareness, safe site, foreign bodies, fever, pressure ulcers, infection, wound protection, preoperative skin preparation, gown and glove procedures, surgical drapes, removal of Foley catheters, glycemic management, antibiotic administration and environmental controls. Databases searched include PubMed, Cochrane, National Guideline Clearinghouse, and National Institutes of Health. | Weighting According to a Rating Scheme | Clinical Highlights Preoperative verification process includes patient identification, procedure(s), site(s), laterality and level. Process is confirmed by source documents, consent form, medical record and discussion with the patient. Additional verification must occur at designated perioperative points. All procedure sites, including level, position, laterality, multiple sites/digits in same anatomic location, and bilateral procedures will be marked with surgeon's initials. Surgeon should follow preoperative verification process prior to marking sites. Initials must be visible at time of incision. Anatomical diagram shall be used to identify surgical site not visible through surgical drape. Procedures involving level will have preoperative imaging available in area where procedure is performed. Intraprocedure imaging with opaque instruments marking specific bony landmarks will be compared to preoperative imaging Time-Out is performed just prior to start of procedure (after surgeon gowned) with active verbal confirmation by all professionals involved. Repeat Time-Out will be performed for multiple procedures or position changes. Intraoperative pause performed for procedures involving level, implants and/or laterality after orifice or midline entry. A pre-procedure briefing will be conducted to present the plan for the procedure and confirm with team members what will be needed during the procedure and when it will be needed. When a hand-off is required, a structured process should be followed. A Hard Stop will occur when either the verification process is incomplete and/or a discrepancy is identified. The procedure will not proceed until the discrepancy is resolved. Baseline counts should be effectively and reliably performed for soft goods and sharps. Imaging is required if the final count is unable to be reconciled.
Application of the Joint Commission “Universal Protocol for preventing wrong site, wrong procedure, wrong person surgery” to the practice of interventional radiology114 | To provide guidelines for a safe, accurate, and consistent process for verifying the interventional procedural treatment site. | All patients having an interventional radiology procedure. | Incidence of wrong site, wrong person, or wrong procedure surgery. | Literature search performed using Medline database from 1980 to 2009. A critical review of peer-reviewed articles is performed with regard to the study methodology, results, and conclusions. Qualitative weight of these articles is assembled into an evidence table. | Expert Consensus (Delphi) Standards documents of relevance and timeliness are conceptualized by the Standards of Practice Committee members. When evidence of literature is weak, consensus is reached by a minimum of 12. Used a Modified Delphi Consensus Method (80% agreement). | Planning/Evaluation. Patient should participate in the planning of procedure. If possible, indicate the side and site at the time of procedure scheduling or preprocedural evaluation (by referring staff) in IR clinic. All potentially necessary images/reports are available at time of procedure. Mark or annotate region of interest on films/images. Preprocedural Marking. The interventional radiologist or designee are responsible for insuring that correct structure and side are identified on previous studies, may require marking a film with intended site of treatment. Patient marking necessary only when direct puncture into area of interest is based on external landmarks and possibility for left/right or level errors. Time Out. Time out should be performed and preprocedural information with staff and physicians performing procedure, including a review of patient's orientation. Confirm correspondence between image guidance system image and orientation, and correct patient's information displayed on image monitor before procedure. Postprocedure. Confirm that all permanent images are correctly labeled regarding patient and side before archiving. Success Rates. There is no literature evidence to determine an acceptable success rate in executing these steps. Success rates should approach 100%, but will have to be locally determined and monitored.
Practice Advisory for the Prevention and Management of Operating Room Fires: An Updated Report by the American Society of Anesthesiologists Task Force on Operating Room Fires117 | 1) Identify situations conducive to fire, 2) Prevent the occurrence of OR fires, 3) Reduce adverse outcomes associated with OR fires, and 4) Identify elements of a fire response protocol. | Anesthesiologists or other individuals working under the supervision of an anesthesiologist. | 1) Any OR or procedure area where anesthesia care is provided. 2) Specific subset of fires that occur on the patient, in the airway, or in the breathing circuit. | Advisory is based on findings from literature published since the original Advisory was approved in 2007. Literature obtained from PubMed and other healthcare databases, direct Internet searches, Task Force members, liaisons with other organizations, and from hand searches of references located in reviewed articles. | Findings from the aggregated literature are reported by evidence category, level, and direction. Evidence categories refer specifically to the strength and quality of the research design of the studies. A directional designation of benefit, harm, or equivocality for each outcome was indicated. | Advisory for Education. All anesthesiologists should have fire safety education for OR fires, with emphasis on risk created by an oxidizer-enriched atmosphere. Advisory for OR Fire Drills. Anesthesiologists should periodically participate in OR fire drills with entire OR team during dedicated educational time. Advisory for Preparation. Anesthesiologist should participate with entire OR team (time out) to determine whether a high-risk situation exists. If a high-risk situation exists, team should take a joint and active role on how a fire will be prevented and managed and each member be assigned a specific fire management task to perform in event of fire. In every OR and procedure area where a fire triad can coexist (i.e., an oxidizer-enriched atmosphere, an ignition source, and fuel), a visible protocol for prevention and management of fires should be displayed and equipment for managing a fire readily available. Advisory for Prevention of OR Fires. Anesthesiologist should collaborate with all members of team throughout procedure to minimize presence of an oxidizer-enriched atmosphere in proximity to an ignition source. Surgical drapes should be configured to minimize accumulation of oxidizers under drapes and from flowing into surgical site. Flammable skin-prepping solutions should be dry before draping. Gauze and sponges should be moistened when used in proximity to ignition source. For high-risk procedures, anesthesiologist should notify surgeon when there is potential for an ignition source to be in proximity to an oxidizer-enriched atmosphere, or for increased oxidizer concentration at surgical site. Any reduction in supplied oxygen to patient is assessed by monitoring (1) pulse oximetry and, if feasible, (2) inspired, exhaled, and/or delivered oxygen concentration. For laser procedures, a laser-resistant tracheal tube is used. Tracheal cuff of laser tube should be filled with saline and colored with an indicator dye. Before activation, surgeon should give anesthesiologist adequate notice, so they can (I) reduce delivered oxygen concentration to minimum required, (II) stop nitrous oxide, and (III) wait a few minutes after reducing oxidizer-enriched atmosphere before approving activation. For cases involving an ignition source and surgery inside airway, cuffed tracheal tubes should be used, if appropriate. Anesthesiologist should advise surgeon against entering trachea with ignition source. Before activating ignition source inside airway, surgeon should give anesthesiologist adequate notice, and then follow steps I-III above. For moderate or deep sedation, an ignition source, and surgical site around face, head, or neck, anesthesiologist and surgeon should develop a plan for level of sedation and supplemental oxygen, and consider a sealed gas delivery device (also if exhibits oxygen dependence). * If moderate or deep sedation is not required, and patient does not exhibit oxygen dependence, consider an open gas delivery device. Before activating ignition source around face, head, or neck, surgeon should give anesthesiologist adequate notice, then they should (1) stop delivery of supplemental oxygen or reduce oxygen concentration to minimum required and (2) wait a few minutes after reducing oxidizer-enriched atmosphere before approving activation. Advisory for Management of OR Fires. When an early warning sign is noted, halt procedure and call for an evaluation of fire. When a fire is present, immediately announce fire, halt procedure, and initiate fire management tasks. For fire in airway or breathing circuit, as fast as possible: * Remove tracheal tube; Stop flow of all airway gases; Remove all flammable and burning materials from airway; Pour saline or water into airway. For a fire elsewhere on or in patient, as fast as possible: * Stop flow of all airway gases; Remove all drapes, flammable, and burning materials from patient; Extinguish all burning materials. If the airway or breathing circuit fire is extinguished: * Reestablish ventilation by mask, avoid supplemental oxygen and nitrous oxide; Examine tracheal tube for retained fragments; Consider bronchoscopy to assess injury and remove debris; Assess patient's status and devise a plan for ongoing care. If the fire is elsewhere on or in the patient is extinguished: * Assess patient's status and devise a plan for ongoing care; Assess for smoke inhalation injury if patient was not intubated. If the fire is not extinguished after first attempt: Use carbon dioxide fire extinguisher in, on, or around the patient. If fire persists: Activate fire alarm; Evacuate patient, if feasible; Close door to room to contain fire and do not reopen or attempt to reenter; Turn off medical gas supply to room.

We assessed the quality of the guidelines with the AGREE II tool. The assessed domains and scoring guide are shown in Table 8. While all guidelines scored about equally well in the stakeholder involvement, there were large differences in the other domains, for examples: rigor of development (low of 23 to high of 50) and editorial independence (low of 5 to high or 14), as shown in the table.

Table 8 AGREE Items and Domains Including Quality Ratings of the Four Guidelines

Agree II Domain & Criteria | Guideline Assessment
DOMAIN 1. SCOPE AND PURPOSE | SIR: Preventing wrong site, wrong procedure, wrong person surgery | ICSI: Retained foreign objects during vaginal deliveries | ICSI: Perioperative protocol | ASA: Operating room fires
1. The overall objective(s) of the guideline is (are) specifically described. | 5 | 7 | 7 | 7
2. The health question(s) covered by the guideline is (are) specifically described. | 2 | 7 | 7 | 6
3. The population (patients, public, etc.) to whom the guideline is meant to apply is specifically described. | 2 | 6 | 7 | 6
Total of Domain 1: | 9 | 20 | 21 | 19

DOMAIN 2. STAKEHOLDER INVOLVEMENT
4. The guideline development group includes individuals from all relevant professional groups. | 5 | 6 | 6 | 7
5. The views and preferences of the target population (patients, public, etc.) have been sought. | 7 | 7 | 7 | 7
6. The target users of the guideline are clearly defined. | 7 | 7 | 7 | 7
Total of Domain 2: | 19 | 20 | 20 | 21

DOMAIN 3. RIGOR OF DEVELOPMENT
7. Systematic methods were used to search for evidence. | 2 | 4 | 7 | 5
8. The criteria for selecting the evidence are clearly described. | 1 | 1 | 1 | 5
9. The strengths and limitations of the body of evidence are clearly described. | 1 | 4 | 7 | 7
10. The methods for formulating the recommendations are clearly described. | 6 | 2 | 2 | 7
11. The health benefits, side effects, and risks have been considered in formulating the recommendations. | 7 | 7 | 7 | 7
12. There is an explicit link between the recommendations and the supporting evidence. | 1 | 3 | 7 | 2
13. The guideline has been externally reviewed by experts prior to its publication. | 7 | 5 | 5 | 7
14. A procedure for updating the guideline is provided. | 1 | 7 | 7 | 2
Total of Domain 3: | 26 | 33 | 43 | 42

DOMAIN 4. CLARITY OF PRESENTATION
15. The recommendations are specific and unambiguous. | 2 | 6 | 7 | 7
16. The different options for management of the condition or health issue are clearly presented. | 3 | 7 | 7 | 7
17. Key recommendations are easily identifiable. | 1 | 7 | 7 | 7
Total of Domain 4: | 6 | 20 | 21 | 21

DOMAIN 5. APPLICABILITY
18. The guideline describes facilitators and barriers to its application. | 1 | 7 | 7 | 1
19. The guideline provides advice and/or tools on how the recommendations can be put into practice. | 1 | 6 | 6 | 5
20. The potential resource implications of applying the recommendations have been considered. | 1 | 1 | 1 | 1
21. The guideline presents monitoring and/or auditing criteria. | 1 | 7 | 7 | 1
Total of Domain 5: | 4 | 21 | 21 | 8

DOMAIN 6. EDITORIAL INDEPENDENCE
22. The views of the funding body have not influenced the content of the guideline. | 1 | 1 | 7 | 4
23. Competing interests of guideline development group members have been recorded and addressed. | 6 | 7 | 7 | 1
Total of Domain 6: | 7 | 8 | 14 | 5

Note: We requested additional information on the methodology used in developing the 2009 Quality Improvement Guidelines for Preventing Wrong Site, Wrong Procedure, and Wrong Person Errors: Application of the Joint Commission “Universal Protocol for Preventing Wrong Site, Wrong Procedure, Wrong Person Surgery” to the Practice of Interventional Radiology. The organization was unable to provide us with additional details regarding their methods, which is therefore reflected in the ratings for the AGREE II criteria for rigor of development. However, they did make two comments in response. 1) Since their 2009 publication, wrong site prevention standards set by the JCAHO have changed so most hospitals have revised their practices since their publication. 2) The society has a consensus processes, but the manuscript was largely a summary of the cited literature, a review of JCAHO policies at the time it was written, and the opinion of the authors in collaboration with the SIR Standards of Practice Committee.

Based on the AGREE II criteria the overall quality was high for stakeholder involvement and scope and purpose. There was considerable variability for the other domains of guidelines development and most had methods problems with regards to transparency and rigor of development. Also, two of the guidelines were developed for one specialty (interventional radiology or obstetrics). The obstetrical guideline was limited to the narrow adverse event of retained objects during vaginal delivery.

Common themes found across guidelines were the regular use of checklists, importance of standardized communication between the surgical team members, and multiple rechecking throughout the operative process. Specific steps and protocols for preventing wrong site surgery, retained foreign bodies, and surgical fires were outlined in detail for all guidelines. In terms of the quality of these guidelines, the AGREE II scores for “rigor of development” varied between 26 and 43 points for the 4 guidelines. By comparison, an assessment of recent guidelines by the US Preventive Services Task Force scored 51 points on the AGREE II scale.

## KEY QUESTION #4 What is the effectiveness of the individually identified interventions for the prevention of wrong site surgery, retained surgical items, and surgical fires?

The 70 identified intervention evaluations are documented separately for each type of event (wrong site surgery, retained surgical items, or surgical fires). Data from VA facilities are highlighted in a subgroup analysis. Strength of evidence assessments are shown for each event.

### Interventions to Prevent Wrong Site Surgery

We identified a large number of intervention evaluations addressing the prevention of wrong site surgery (49 studies).

To date, five studies have been published that evaluate the effect of the Universal Protocol mandate. The evidence table summarizes the compliance, the effect on near misses or composite outcomes, and the effect on event incidents.

Table 9 Evidence Table Intervention Evaluation Wrong Site Surgery – Universal Protocol

ID | Country, setting/surgery type | Study design N F/u | Intervention focus | Intervention components | Compliance | Other/intervention-specific outcomes | AE | Effect on Near misses or composite outcomes | Effect on event incidents
James, 2012^42^ | US, ABOS database, orthopedic surgery (hand, arthroscopic and spine surgery) | Time series, N=1,291,396 cases F/u: 6 years | Universal Protocol mandate | Preoperative verification of pt and site, surgical site marking, time-out before procedure for repeat verification | n/a | n/a | n/a | Incidence rate (wrong site local or regional anesthesia, wrong site skin incision, wrong site surgical exposure, incomplete operation on the wrong site, wrong procedure, wrong side, wrong digit, wrong level of spine) 1999-2005: 0.0072%, rate after mandate (2006-2010): 0.0062% (p=0.55); non-spine incidents 1999-2005: 0.0042%, 2006-2010: 0.0028% (p=0.303) | n/a
Mulloy, 2008^32^ | US, members of AORN and American Hospital Association | Pre-post N=519 respondents CSSTK surgery, 325 UP survey, N=91 for near miss data | Universal Protocol, AORN Correct Site Surgery Toolkit | Universal Protocol for Wrong Site, Wrong Procedure and Wrong Person Surgery, AORN Correct Site Surgery Tool Kit including CD rom educational program, pocket card, template for policy development, copy of protocol and guidelines for implementing, FAQ, letters to RN, physician, CEO and risk managers, pt info | CSSTK: 97% for 2 pt identifiers, 81% for site marking, 74% for time out; UP: 91% 2 pt identifiers, 69% site marking, 45% time out | 68% changed practices, 45% revised hospital policy after CSSTK, 92% found CSSTK helpful, 90% felt empowered to stop procedure | Survey showed criteria too flexible, diverse interpretations, more education required for improved uptake, lack of consequences for non-performers | 7,585 events between 7/2004-12/2004, 11,607 events in 2005, 7,320 events in 2006 | Rates per 100,000 surgeries: 1.93 in 2001, 3.30 in 2002, 2.91 in 2003, 3.77 in first half of 2004, 4.27 in second half of 2004, 3.67 in 2005, 3.14 in 2006 (n.s.)
Simon, 2007;^47^ Simon 2007^57^ | US, State health department, ophthalmology | Pre-post N=n/a F/u: 14 mos | Universal Protocol | Universal Protocol in effect | n/a | n/a | n/a | Pre: 52 surgical confusions (wrong pt, wrong eye, wrong eye block, wrong implant, wrong transplant) in 49 months (7.4 incidents per 100,000 procedures), post: 10 incidents in 14 mos (5/100,000 procedures), p=0.26 | n/a
Starling, 2011^118^ | US, academic dermatologic surgical practice, skin cancer pts | Post only N=7,983 procedures F/u: n/a | Universal Protocol | Joint commission protocol implemented; pre-procedure pt ID verification (wristband), site identification with surgeon and pt input, photo of site, pre-operative Time Out | n/a (100% implied) | n/a | n/a | n/a | 0 wrong site surgery events in charts of 7,983 cases
Vachhani, 2013^48^ | US, academic neurosurgical practice | Pre-post N=22,743 surgeries F/u: 7 years | Universal Protocol | Pre-procedure verification of pt ID, surgical site, pre-operative time-out | n/a (non-compliance contributed to 1 of 3 wrong site cases) | n/a | n/a | 12 incidents (0.07%, all wrong level spine surgery) in 5 years prior to Universal Protocol; 3 incidents (0.02%, wrong level spine, wrong side cranial surgery) in 7 years after implementation (p<0.001) | 2 events of wrong level spine surgery that were not identified as an error before the end of the procedure occurred pre-Universal Protocol, 1 occurred post-Universal Protocol

Notes: ABOS: American Board of Orthopaedic Surgery; AE: adverse event associated with intervention; CSSTK: Correct Site Surgery Toolkit; F/u: Follow up; mos: months; ID: identification; N: number of patients or procedures

Five large US studies investigating the effect of the Universal Protocol mandate were identified. A 12-year time series reported by James et al.42 used the American Board of Orthopaedic Surgery database to which candidates for board certification submit a list of their cases. The study found a reduction in incidence rates of wrong site local or regional anesthesia, wrong site skin incision, wrong site surgical exposure, incomplete operation, wrong procedure, wrong side, wrong digit, or wrong level of spine after the mandate (0.0072% to 0.0062%) but the results were not statistically significant (p=0.55), even when cases related to the spine were excluded (p=0.303). Similarly, Simon et al. using Ophthalmic Mutual Insurance Company data and cases reported to NYPORTS47,57 found a reduction from 7.4 to 5 surgical confusions (wrong implant, transplant, eye, eye block, patient, or procedure) per 100,000 procedures in the 14 months after the mandate (p=0.26). However, a study with a 7 year followup period48 reported a statistically significant (p<0.001) reduction from 0.07% wrong site surgery (all wrong level spine surgery events) versus 0.02% (wrong level spine and wrong side cranial surgery events) analyzing the morbidity and mortality database of the department of neurosurgery. A study analyzing two national mailed surveys to 800 randomly selected registered nurse members from the Association of periOperative Registered Nurses and 800 acute care hospitals from the American Hospital Association database showed no statistical significant reduction of reported wrong site surgery events in 2006 but respondents found the Correct Site Surgery Tool Kit helpful and indicated that the elements in the Universal Protocol were detecting system flaws.32 A post-only study noted that at their institutions, no wrong site surgery event occurred according a chart review for 7,983 patients undergoing skin cancer treatment, the pre-Universal Protocol rate was not reported.

We identified 21 studies in the international literature evaluating the effects of implementing a time out procedure, a surgical checklist, pre- or peri-surgical briefings, or verification protocols. Some interventions were local operationalization of the Universal Protocol elements 1) preoperative verification of the patient, 2) marking of the surgical site, and 3) performing a Time Out before the procedure begins. Other studies focused on the introduction of checklists that guided some or all stages. The studies are summarized in the Evidence table.

Table 10 Evidence Table Intervention Evaluation Wrong Site Surgery – Preoperative Verification, Site Marking, Time Out, Briefing and Checklist Implementations

ID | Country, setting/surgery | Design N F/u | Intervention focus | Intervention components | Compliance | Other/intervention- specific outcomes | AE | Effect on near misses | Effect on event incidents
Ablinger, 2010 119 | Switzerland, urban medical center | Pre-post N=15,461 cases F/u: 18 mos | Surgical checklist based on WHO Safe Surgery Checklist | Implementation of 13-item surgical safety checklist “4-step-protocol” for every patient undergoing surgical procedure in OR | n/a | n/a | n/a | n/a | Pre: 1 event in 4,901 cases over 52 months. Post: 0/10,560 cases over 18 months (n/s)
Bergal, 2010^120^ | US, orthopedic surgery | Post-only, N=200 pts F/u: n/a | Pt participation in site marking | Involving pts in preoperative site marking; detailed verbal and written instructions; mark surgical site with “YES” prior to arrival in pre-op | 68.2%; correct site: 67%, correct marking: 62% | n/a | n/a | n/a | 0/200 wrong site surgery events
Butcher, 2011^121^ | US, Minnesota facilities | Pre-post N=n/a F/u: n/a | Minnesota Time Out Process | Initiated by Minnesota Safe Surgery Coalition; surgeon-initiated time out with specific roles for all team members, with goal to have the Time Out become culturally accepted and a community standard | n/a | n/a | n/a | n/a | 1 wrong site procedure every 30 days compared to 1 every 12 days before rollout
DeFontes, 2004^122^ | US, Kaiser Permanente medical center | Pre-post N=6,795 procedures/year, 59 OR staff, 60 surgeons F/u: 1 year | Briefing | Preoperative safety briefing; similar to preflight checklist; surgeon, anesthetist, circulator, scrub discuss background of case, assess risks, and offer relevant information and expectations | n/a | Good safety climate: 51.1% to 62.9%; minimal cost | n/a | Pre: 2 near misses, post: 5 | 3 wrong site surgeries in year pre-intervention, 0 in year since implementation
DiGiovanni, 2003^123^ | US, foot-and-ankle practice | Post-only, N=100 pts F/u: n/a | Pt participation in site marking | Involving pts in pre-operative site marking; detailed verbal and written instructions: mark non-operative site with “NO” prior to arrival in pre-op | Marked: 63%; fully compliant: 59%; marked, but not fully compliant: 4%; non- compliant: 37% | n/a | n/a | n/a | 0/100 wrong site surgery events
Duggineni, 2011^124^ | UK, university hospital | Post only N=n/a F/u: n/a | WHO surgical safety checklist | Checklist instituted for all minor oral surgical procedures under local anesthetic | 100% | n/a | n/a | n/a | 0 wrong side surgery
Garnerin, 2008^125^ | Switzerland, academic medical center, anesthesia practice | Pre-post N=252,855 procedures F/u: 1 year | Verification protocol | Verification protocol for checking pt ID and site of surgery developed by interdisciplinary team; anesthetist to perform checks, pt asked to participate if able using open-ended questions (no prompting), corroborated with medical record, wristband, and scheduling information, site compared with medical record, surgeon check and schedule; protocol distributed to all anesthesia staff as pocket-sized document; audit and some feedback | Compliance improved for all but 1 criterion; ranged from 59% (full compliance with protocol pt ID check) to 99% (ID wristband) | n/a | Some staff objected (“I already know that pt”; “It's the obvious surgical site”); lack of collaboration with surgical services | n/a | Pre: 4 wrong site anesthesia and 0 wrong site surgery in 181,710 procedures; 0 cases of wrong pt or wrong site anesthesia during and post intervention (71,145 procedures)
Harrington, 2009^126^ | Iraq, US Army OR | Post only N=900 procedures F/u: 15 mos | Time Out | Time Out procedure, responsibility of routinely reinforcing rests with preoperative nurses; site verification procedure; surgical Time Out consisting of pt ID, procedure, location by circulating nurse, with assent from all members of peri-operative team | n/a | Practice supports team building | n/a | n/a | 0 events in 900 procedures
Johnston, 2009^127^ | Canada, academic orthopedic practice | Pre-Post N=48 procedures pre, 231 cases post F/u: 1 year | Time Out | Pre: Site signing - initials of operating surgeon or surgical resident in surgical field documentation; Post Time Out in addition to existing practice | Pre: in 67% emergent and 90% elective cases initials visible; post: 61% and 83%; Time Out prior to skin incision: 70%, after incision: 19%, not performed: 11% | n/a | n/a | n/a | 0 wrong site surgery pre and post
Khoshbin, 2009^128^ | Canada, pediatric hospital | Pre-post N=n/a F/u: 2 years | Pre-operative OR briefing and Time Out | Pre-op briefing (huddle): diagnosis, equipment needs, positioning, special considerations before start of the day; peri-operative surgical Time Out: presence of correct pt, marking of correct site and side, correct pt position, procedure to be performed, availability of implants/equipment, statement any time team members should voice concerns, etc. | Pre op briefing completion rate 64.1%; Time Out 99.1% | Survey (scale 1-5): team discussion important for pt safety: surgeons 4.4, anesth. 4.7, nurses 4.9; pre-op briefing has improved safety: surgeons 3.3, anesth. 3.1, nurses 4.0; Time Out has improved safety: surgeons 3.3, anesth. 3.1, nurses 4.2 | Some surgeons and anesthesiologists felt pre-op briefing had little to do with safety (more an annoyance, staff overburdened with too many changes) | n/a | Since implementation of both interventions 0 wrong side surgeries (1 year), compared to 1-2 events per year previously (8 events in 3 years)
Knight, 2010^30^ | US, community-academic health system | Post only N=112,500 procedures F/u: 4.5 years | Anatomic marking form | Alternative to Universal Protocol; procedure and intended surgical site marked in clinic, signed by pt; form delivered to pre-op, where site is marked by perioperative nursing staff | Self-reported adherence 65% for most or all procedures | n/a | 7% were very dissatisfied with anatomic marking form and alternative process | n/a | 1/112,500 event post-intervention in 4.5 years (skin lesion mistakenly removed and intended lesion missed)
Lee, 2007^44^ | US, oral and facial surgery center, UCSF | Pre-post N=10,595 tooth extractions (pre) F/u: 10 mos | Time Out protocol, guidelines for wrong tooth/wrong site surgery | Clinical guidelines developed and circulated to educate; Time Out protocol implemented | n/a | n/a | n/a | n/a | Post: 0 wrong tooth or wrong site surgery in 10 mos, pre: 5 events in 2 years (10,595 extractions; event rate was 0.047% per extracted teeth, 0.09% per N of pts)
Lee, 2010^90^ | US, community non-profit institution, pediatric pts | Pre-post N=309 (pre), 274 (post) F/u: n/a | Extended Time Out | Pt safety briefing checklist includes confirmation of ID, procedure, technical details, special equipment, etc.; before anesthesia induction; aims to improve communication and teamwork | 100% (all members of surgical team) | Improved confidence and prepared for procedure due to improved communication | Time to incision for elective surgery 24 ± 3 vs 25 ± 8 min (p=0.33); urgent: 36 ± 7 vs 32 ± 16 min (p=0.25) | Post: 1 (without briefing surgery would have started on wrong side) | 1/274 wrong site surgery post intervention (left inguinal hernia repaired, then right side (=scheduled) repaired, pre: similar events pre and post implementation
Lee, 2012^129,130^ | New Zealand, 3 major elective surgery hospitals | Post only N=35,416 operations analyzed F/u: first 7 mos and 12 mos 4 years later | Checklist | Preoperative surgical safety checklist functioning as Time Out; carried out after anesthesia induction, prior to preparation and draping; checklist similar to Pronovost et al.; pt ID, correct consent form, site marked and confirmed, all peri-operative team members in agreement (check each), correct pt position, corresponding set up, concerns | First year 87% complete, 4-5 years later 98% | n/a | Some surgeons refused to be involved in first year (1.2% objections) | 3 near misses, captured by checklist in first year (0.4%), 0 incidents in year 4 and 5 | 0/35,416 wrong site operations
Leonard, 2004^131^ | US, Orange County Kaiser | Post only N=n/a F/u: n/a | Briefing | Peri-operative briefing consisting of four sections for surgeon, circulator, scrub, and anesthesia emphasizing communication and shared expectations; developed by multidisciplinary team; some facilities brief after anesthesia induction, others with pt awake | n/a | Employee satisfaction increased by 19%, perceptions of safety climate improved from good to outstanding | n/a | n/a | Wrong site surgeries went from being a problem to 0 events after implementation
Lyons, 2010^132^ | US, academic neurosurgical practice | Post only N=6,345 pts F/u: 8 years | Checklist | Operative Site Checklist; confirmation of pt ID, confirmation of correct medical record, correct x-ray, correct operation, correct consent form, etc.; completed by attending surgeon | 99.5% compliance; emergency cases more likely to be non-compliant initially | Successful spread to other campuses | n/a | n/a | 0/6,345 wrong site surgeries in 8 years
Makary, 2007^133^ | US, academic medical center, surgery | Pre-post N=n/a F/u: n/a | Briefing | Tool to enhance communication; name introduction, surgeon leads Time Out, care teams discuss and mitigate potential safety hazards | 100% compliance with OR briefing protocol | Self report: “Preoperative discussion increased my awareness of the surgical site and side”: pre-briefing mean 3.18 (scale 1-5), post 3.74 (p<0.001); “Surgical site was clear to me before incision”: pre 4.45, post 4.75 (p<0.002) | n/a | n/a | n/a
Norton, 2010^134^ | US, academic children's hospital | Pre-post N=n/a F/u: n/a | WHO Safe Surgery Checklist for pediatric population | Checklist tailored to pediatric population; 3-part framework: sign in, time out, sign out; mandatory verbal contributions from each member of OR team | 80-90% in pilot; sign in: 85-100%, time out: 95-100%, sign out: 80-100% in implementation period | n/a | Not all surgeons comfortable with responsibility for time out/sign out; more labor intensive than UP | 1 unmarked site; consent, site-marking, and equipment problems | n/a
Reid, 2011^135^ | UK, English NHS Trusts | Post only N=n/a F/u: 2 years | WHO Safe Surgery Checklist | National Patient Safety Agency requiring implementation of WHO checklist for every surgical pt; local adaptations and additions, briefings and debriefings | Checklist 89%; 32% use checklist and briefings; 33% use checklist, briefing, and debriefing | n/a | Negative clinician attitudes: 77%; obligation rather than commitment/tool to improve communication and teamwork: 78%; not having enough time: 37% | 41% reported checklist captures near misses | n/a
Wauben, 2011^136^ | The Netherlands, 5 academic and community hospitals | Post only N=522 time outs F/u: n/a | Time out | Use of participatory design to create time out procedure combined with team-based debriefing | 81%, partially in 2%, not at all in 5%; documentation missing in 12% | Average time out 96 seconds (SD=63s); average debriefing 58 seconds (SD=58s) | 1 hospital stopped participating after 1 day (intervention too time consuming) | 18 risk sensitive events including incorrect pt history (8), wrong side identified (2), pt identification (5) | n/a
Wood, 2009^137^ | US, community hospital | Pre-post N=n/a F/u: n/a | Site marking | Surgeons mark site in pre-op area; standardized order sets; 2-year culture of safety initiative | n/a | n/a | Initial pushback from surgeons | n/a | No event before or after implementation

Notes: AE: adverse event associated with the intervention; CI: confidence interval; F/u: Follow up; mths: mos; ID: identification; N: number of patients, participants, or procedures; NHS: National health service; OR: operating room; pts: patients; UCSF: University of California San Francisco

Ten studies were post-only interventions reporting their experiences with interventions after implementation without reporting on a comparator. The other studies were pre-post studies comparing the effects of the intervention to a historic comparison period.

One study assessed the effects of a verification protocol developed by an interdisciplinary team combined with audit and feedback125 and reported no cases of wrong patient or wrong site anesthesia during and post intervention in a one year followup period with 71,145 procedures after previously experiencing four wrong site anesthesia cases (none resulted in wrong site surgery).

Four studies focused primarily on site markings. One study used an anatomic marking form to indicate the intended surgical site, signed by the patient at the same time as the surgical consent form, and the surgical site was then marked by preoperative nursing staff.30 The post-only study reported one incident of wrong site surgery (a skin lesion was mistakenly removed and the intended lesion was missed) in 112,500 patients over 4.5 years. One intervention required surgeons to see patients in the pre-op area and mark the site before entering the operating room as part of a culture of safety initiative, no events were reported for pre- or post-intervention periods; however, the observation period was not specified.137 Patient participation in the site marking process was tested in two studies.120,123 Both studies reported no incidents of wrong site surgery post intervention but noted that the patient markings were not reliable and compliance was only between 59 and 68%.

Eight studies focused explicitly on the time out process. One publication121 reported that the time out campaign initiated by the Minnesota Safe Surgery Coalition has improved the incidence rate in Minnesota facilities so that events now occur every 30 days compared to every 12 days before rollout. A post-only study of a US Army operating room in Iraq126 reported that their protocol has been successful in 900 procedures; all personnel have to assent when the information is reviewed; the responsibility of reinforcing the time out rests with the perioperative nurses. A Canadian orthopedic practice added a time out procedure to their surgical site signing process; there were no wrong site surgical procedures before and after the intervention.127 Lee et al.90 tested an extended time out procedure that was designed to promote communication and teamwork. One near miss occurred and the authors thought that without the intervention the procedure would have started on the incorrect side, however, one incident of wrong site surgery also occurred (left inguinal hernia repaired but right inguinal hernia was scheduled). Three hospitals in New Zealand129 reported that a checklist, introduced to facilitate the time out process, prevented three potential wrong site surgery events in a 17--month long observation period (months immediately following the intervention and four years later). A study addressing the prevention of wrong site tooth extractions44 reported no events in 10 months after the introduction of a clinical guideline and implementing a time out protocol (the event rate was 0.047% per extracted teeth and 0.09% per number of participants).

Nine publications reported experiences with introduced surgical briefings, often supported by a checklist. A study at a Kaiser Permanente medical center122 showed that a preoperative safety briefing was associated with no incident of wrong site surgery compared to three events in the year pre-intervention. The introduction of pre-operative and peri-operative operating room briefings resulted in no wrong site surgery in over a year compared to one to two events per year previously in a Canadian children's hospital.128 Lyons132 reported no wrong site surgery events in eight years after initiating an intraoperative checklist program at the Department of Neurological Surgery at Mayo Clinic in Arizona (pre-intervention rate not known). One publication131 reported that wrong site surgeries, which had been a problem in the past, have not occurred since introducing a perioperative briefing, however the followup period and pre-intervention data were not specified. Makary133 showed that operating room briefings reduced staff's perceived risk for wrong site surgery but data on event incidents were not reported.

Four studies evaluated the use of the WHO surgical safety checklist; a Swiss study reported no wrong site surgery in 10,560 cases since implementation119, a second study also reported no wrong side surgery after instituting the checklist but did not specify the followup period or the number of procedures.124 One publication described that the reported benefits of implementing the checklist across English NHS Trusts included that more near misses were captured but the study did not report numerical data on wrong site surgery incidents135 and a study adapting the checklist for pediatric patients also reported successfully identifying near misses.134

Only selected studies30,90,125,128,129,135 reported adverse events of the interventions, such as staff experiencing the intervention as an additional burden. Lee et al.,90 the only study reporting comparative data, found that the introduced extended time out protocol did not statistically significantly increase the time to incision.

We also identified 13 studies not directly focusing on elements of the Universal Protocol. The studies evaluated team training interventions or interventions primarily targeting the safety climate in the organization. The identified studies are summarized in the evidence table.

Table 11 Evidence Table Intervention Evaluation Wrong Site Surgery – Team Training, Education, Other Approaches

ID | Country, setting/surgery | Design N F/u | Intervention focus | Intervention components | Compliance | Other/intervention-specific outcomes | AE | Effect on Near misses | Effect on event incidents
No author, 2009^138^ | US, academic medical center | Pre-post N=n/a F/u: 5 years | Training | Multi-year training program incorporating interdisciplinary, team-based format, building work flow into policies | n/a | n/a | n/a | n/a | Several episodes of wrong site events to 0 events for >5 years
Chang, 2004^139^ | Taiwan, academic medical center, oral surgery practice | Pre-post N=7800-8500 extractions per year F/U: 3 years | Education/Clinical guideline | Clinical guideline to prevent erroneous tooth extractions; description in written order, inform pt about tooth position and reason for removal, operator should verify order with pt, communicate with referring dentist if unclear, check tooth position before and after forceps application; staff training | n/a | n/a | n/a | n/a | 8 wrong site extractions in 3 years pre-intervention (annual rate 0.026%, 0.025%, 0.046%), 0 events 3 years after (p<0.01)
DeJohn, 2012^140,141^ | US, eight hospitals and ambulatory surgical centers | Pre-post N= n/a F/u: n/a | Joint Commission's Center for Transforming Healthcare project | Targeted Solutions Tool (TST); Robust Process Improvement methods—including Lean Six Sigma and change management—to pinpoint causes, and develop targeted solutions; 29 main causes of wrong site surgery identified within 3 sites of care: scheduling, pre-op/holding, OR; individual solutions developed to avoid the identified risks; audits | n/a | n/a | n/a | Decreased cases with identified risks from 39% to 21% in scheduling, 52% to 19% in pre-op, and 59% to 29% in the OR (p<0.001); reduced incidence of cases with >1 defect (scheduling 57%, pre-op 72%, OR 76%) | n/a
Johnson, 2012^142^ | US, community health system | Pre-post N=n/a F/u: 1 year | Pt safety course to create a culture of safety | Crew Resource Management, TeamSTEPPS, communication techniques; video vignettes featuring coworkers, audience response system to engage learners and promote participation, mandatory attendance; SBAR, callout and check back technique | Nearly all intended participants | n/a | n/a | n/a | During the year before course implementation 12 root cause analysis requiring events occurred, 4 in the year after
Logan, 2012^143^ | US, academic medical center | Pre-post N=98 cases pre, 100 post F/u: 1 year | Audit | Clandestine audit of Universal Protocol, feedback/discussions; permanent white board template with prompts for required information implemented in addition to existing Time Out, presurgical checklist | Compliance increased in all dimensions, Time Out 98%, checklist 90% | n/a | n/a | 0 near misses pre and post | n/a
Mallett, 2012^83^ | US, academic medical center | Pre-post N=n/a F/u: 1 year | Process Redesign | Universal Protocol and WHO surgical checklist plus common cause analysis results (VA Triggering and Triage Cards) addressed by multidisciplinary team through process redesign; focused education initiatives for all faculty, residents, and clinical staff; creation of a zone of silence to minimize distractions during peri-procedural time period | Pre-procedure verification: 100%; site marking: high compliance; limited for Time Out | n/a | n/a | n/a | Pre: 8 wrong site surgery events in 21 mos, post: 0 event in 1 year
Neily, 2012^87^ | US, VA | Post only N=132 F/u: 2 years | Education | Sharing of lessons learned through quarterly surgery adverse events reports and surgery root cause analysis lessons | 76% of respondents had seen surgical lessons that were shared | 75% gained new knowledge to prevent incorrect surgery | n/a | n/a | n/a
Neily, 2009^33^ | US, VA | Pre-Post N=n/a F/u: 2 years | VA directive Ensuring Correct Surgery and Invasive Procedures | Directive consistent with Universal Protocol (6/2004 update) | n/a | n/a | n/a | OR close calls increased from appr. 0.5 events per month to 2; reported non OR close calls decreased slightly to appr. 0.2 reports/month | OR events increased from appr. 1.5 reports per month to 2; reported non-OR events increased from appr. 1 to 2 reports (estimated from graph)
Neily, 2011^34^ | US, VA | Timeseries N=n/a F/u: 3 years | Medical Team Training | Training requires 2 mos planning with core change team; 1-day face to face learning session, mandatory attendance, 12 mos follow-up and coaching; emphasis on pre-op briefing and post op debriefing; in addition to VA directive for ensuring correct surgery | n/a, training presumably 100% | n/a | n/a | Rate of close calls increased from 1.97 per month to 3.24 (p≤0.001) | Event rate decreased from 3.21 to 2.4 per month (p=0.02); highest harm category (safety assessment code 3) dropped 14% (rate ratio 0.86; 95% CI 0.75, 0.97; p=0.02) each year (drop of 0.17 events per 100,000 surgeries per year)
Paull, 2013^144^ | US, VA | Post only N=76 trainees F/u: n/a | Education | Simulated thoracentesis with variable scenarios designed to test teamwork and communication in preventing or catching errors before they cause harm to pts | n/a | Self reported confidence in ensuring correct surgery and invasive procedures improved | n/a | n/a | n/a
Ricci, 2012^145^ | US, academic health system | Pre-post N=517 team members, 19,000 cases annually F/u: 2 years | Crew Resource Management program | System of effective teamwork, open communication, and optimized decision making in high-risk environments applying aviation techniques; initial 6-h training program (education, case-study discussions, team building exercises etc.), mandatory for all OR personnel; tools (checklists, feedback mechanisms) emphasis on communication (e.g., using the names of team members) and shared expectations during and at end of procedure; refresher courses planned | Compliance with local “time-out” policy increased from 6.7% to 99% 4 mos after training | Malpractice payout 4 years before: $793,000, after: $0 | n/a | n/a | Annual wrong site surgery and RFI incidences ranged from 3 (0.016) to 7 (0.037) in 3 years before implementation; first 14 mons after: 0 events, second year: 5 events (0.026)
Russell, 2013^146^ | US, academic medical center | Post only N=728 preoperative regional blocks F/u=1 year | Training/Team development | Development of dedicated perioperative block nurse team; 3-week competency-based orientation program, orientation manual; simulations with regional anesthesiologists; pre-procedural time-out | n/a | Perioperative efficiency increased by 26%, service productivity increased by 12%, on-time OR starts increased by 7% | n/a | No wrong-site blocks during study period | n/a
Zohar, 2007^147^ | US, community hospital | Pre-post N=15,856 pts F/u: n/a | Zero tolerance policy, peri-operative checklist | Education phase for involved caregivers; pre-operative readiness checklist completed by nurse at each care setting; readiness failures documents for analysis; zero tolerance policy for errors in pt readiness for anesthesia and surgery – pt returned to parent department, surgical procedure delayed until error corrected | n/a | Days between failures increased over time: 6.6 in 2003, 11.2 in 2004, 14.7 in 2005; failure decrease over time: 2004 OR 0.59, 2005 OR 0.49 | n/a | 112 failures (0.71%) including incorrect patient (4), absent/incorrect side identification (34) or pt identification (20) | n/a

Notes: ABOS: American Board of Orthopaedic Surgery; AE: adverse event associated with the intervention; F/u: Follow up; mos: months; ID: identification; NHS: National Health Service; OR: operating room; pts: patients; RFI: retained foreign item; UCSF: University of California San Francisco

The identified studies used diverse interventions to address the prevention of wrong site surgery. Three studies were post-only studies reporting only on the period after the implementation of the intervention without comparative data, the others reported on a historical comparator.

Five interventions focused on team training. Two142,145 used Crew Resource Management, a system of effective teamwork, open communication, and optimized decision making in high-risk environments; one study combined it with TeamSTEPPS, a teamwork system for healthcare professionals to improve patient safety. Both pre-post interventions reported a reduction in a composite outcome (events requiring root cause analysis, wrong site surgery and retained surgical items); the exact effect of the intervention on wrong site surgery alone is not known. One VA setting team training study was identified; described in more detail in the VA subgroup analysis section.34 One study138 reported no wrong site events after implementing a multi-year training program that incorporated an interdisciplinary team-based format for more than five years after having experienced several episodes pre-intervention. No further description of the intervention was reported and despite the success, the organization plans to add additional preventative measures such as a time out script and a checklist based on the WHO checklist. One study implemented a dedicated perioperative block nurse team, successfully avoiding wrong site anesthesia blocks during the one year study period.146

Some studies used, primarily, educational approaches to prevent wrong site surgery. One study143 reported the effects of a clandestine audit by medical students who observed adherence to Universal Protocol requirements. After feedback and discussions, and implementing a whiteboard template with prompts for the required information, compliance increased for all elements and no near misses were identified pre- or post-intervention. A VA setting study reported by Neily et al.87 also used a unique approach, i.e., sharing lessons learned through adverse event reports while an additional VA setting study reported by Paull et al.144 used surgery simulations to train participants. One study developed a clinical guideline to prevent erroneous tooth extractions in combination with staff training and reported a significant improvement in the three years implementing the intervention in a Taiwanese academic medical center.139

Several publications in the existing literature address the initial success associated with the Joint Commission's Center for Transforming Healthcare tool “Targeted Solutions Tool” (TST). Participating hospitals reviewed their procedures to identify weaknesses that could potentially lead to errors, and sought ways to counteract them. Reported risk reductions were 46% in scheduling, 63% in pereop and 51% in the operating room; however the frequency of wrong site surgery incidents has not been reported yet.140,141 One study83 showed the effects of a process redesign that was based on a common cause analysis which used the root cause analysis methodology proposed by the VA National Center for Patient Safety Triggering and Triage Cards. The study reported that after experiencing eight events in 21 months prior to the intervention that no further wrong site procedures, or person events have occurred in the following year. A publication by Neily et al.33 analyzed the effect of the VA Directive Ensuring correct Surgery and Invasive Procedures (see VA subgroup analysis). A multifaceted, cross-organizational study established a zero tolerance policy for documentation failures in the operating room holding area and patients would be returned to the parent department, delaying the surgical procedure, until the error was corrected.147 Incorrect patient and incorrect identification of the side of surgery errors decreased over time; however, the study did not report on the frequency of actual wrong site surgery incidents.

The review also identified nine studies that primarily targeted technical equipment. The studies are summarized in the evidence table.

Table 12 Evidence Table Intervention Evaluation Wrong Site Surgery - Equipment

ID | Country, setting/surgery | Design N F/u | Intervention focus | Intervention components | Compliance | Other/intervention-specific outcomes | AE | Effect on near misses | Effect on event incidents
No author, 2011^148^ | US, community medical center | Pre-post N=n/a F/u: n/a | Reporting simplified | Encouragement of reporting incidents and near misses, procedure for reporting streamlined; Intervention in addition to Universal Protocol | 100% compliance with Universal Protocol | Improved safety culture | n/a | n/a | Pre: 1 event, post: 0
Ammerman, 2006^149^ | US, academic neuro-surgery practice | Post only N=100 pts F/u: n/a | Intraoperative x-ray | Routine intraoperative x-ray to reduce incidence of incorrect level surgery | n/a | n/a | n/a | 15% potential wrong-level laminectomies prevented with x-ray; 15% wrong level exposures | 0/100 wrong site and wrong level laminectomies
Asopa, 2012^150^ | UK, lumbar spine surgery | Post only N=64 F/u: n/a | Imaging technique | Technique to avoid incorrect level lumbar spine surgery; intraoperative fluoroscopy with radiopaque marker ID of level, repositioning and re-imaging of level after skin incision, and re-imaging after surgery to confirm site | n/a | n/a | n/a | n/a | 0/64 cases of incorrect level discectomy
Cima, 2010^29^ | US, academic medical center | Pre-post N=5,299 procedures (pre), 4354 (post) F/u: 1 year | Computerized listing system | Changes to computerized surgical listing system based on error analysis; mandatory entries for laterality | n/a | Reduction in listing errors from 1.5% to 0.54% (gynecologic surgery); from 2.06 to 0.49% (colorectal surgery) | n/a | n/a | Pre: 0 wrong pt surgeries, post: no adverse outcomes from errors
Henley, 2008 91 | UK, single NHS trust hospital | Post only N=40,000 F/u: 1 year | Pt identity band | Identity band placed by pt, info filled in by team members during path to OR, and removed just before incision, band placed in medical record | n/a | n/a | n/a | Minor error rates were similar but identified earlier | n/a
Irace, 2010^151^ | Italy, neurosurgical practice | Post only N=818 procedures F/u: 96 mos | Intraoperative radiograph | To confirm spine level and side; wire placement at desired level pre-operatively, confirmation radiographically prior to laminotomy; verbal confirmation by surgeon | n/a | n/a | No complications | 1 wrong level initially explored in 818 procedures (0.12%) | 0 wrong site surgery events in 818 procedures
Ku, 2011^152^ | Taiwan, medical center | Pre-post N=22,000 pts F/u: 1 year | Radiofrequency ID | Patient Advancement Monitoring System-Surgical, radiofrequency (RFID) to control pt flow process through peri-operative processes, quality and efficiency of care | 100% | Pt ID check correction rates increased from 75% to 100%; 78% felt system was easy to use; 91% felt it was conducive to improving pt ID and promoting surgical safety | n/a | n/a | 0 wrong pt or surgical procedure events pre and post
Nowitzke, 2008^153^ | Australia, academic neurosurgical practice | Post only N=17 F/u: n/a | Computer-assisted image guidance | Technique for thoraco-lumbar level localization; standard image intensifier radiology, adjacent, contiguous images of desired plane displayed; lowest-possible radiation exposure, reproducible technique, versatile, recordable, interpretable by non-specialists | n/a | n/a | No complications | n/a | 0 cases of incorrect level surgery
Upadhyaya, 2012^154^ | US, single academic institution spine surgery | Pre-post N=52 F/u: n/a | Percutaneous fiducial screw placement | Pre-operative placement of percutaneous screw at level of intended surgery using CT guidance, followed by intra-operative fluoroscopy for intraoperative localization | n/a | 0 complications; intraoperative localization fluoroscopy time reduced from 15 to 3 mins | n/a | n/a | Pre and post 0 wrong level surgeries

Notes: AE: adverse event associated with the intervention; F/u: Follow up; mos: months; ID: identification; OR: operating room; pts: patients

Half the identified studies used a post only design, reporting zero events since implementation of the intervention; however, only selected studies specified the followup period. The other studies reported pre-post data; all studies reporting on events reported zero wrong site surgery incidents post intervention.

Five national and international studies reported on imaging techniques designed to prevent wrong site spine surgical procedures and in particular, wrong level spine operations intraoperatively, alone or in combination with other protocols.149-151,153,154

Cima et al29 redesigned the computerized surgical listing process, in particular to avoid errors in laterality, arguing that errors in this early stage of documentation may establish an incorrect mental model for operating room personnel which sends them on a trajectory toward an error unless there is credible conflicting information brought forward. The study reports no adverse outcomes from errors in a one year followup period; there were also no wrong patient surgery before the redesign. A Taiwanese study152 reported their experiences with a radiofrequency patient identification program (Patient Advancement Monitoring System-Surgical). The feedback was generally positive and there were no wrong patient or wrong surgical procedures before and one year after the implementation. A UK study used a patient identify band worn until the moment of surgery when the band was filed with the patient records; the study found minor error rates to be similar but identified earlier and prior to the patient being at risk.91

One study107 simplified the incidence reporting system in order to encourage reporting of incidents and near misses and reported that post intervention 100% compliance with the Universal Protocol and an improved safety culture was achieved. The study reported no further wrong site surgery events; however, the followup period was not specified.

#### VA Subgroup Analysis: Effectiveness of Interventions for the Prevention of Wrong Site Surgery

We identified four studies evaluating interventions and policies within the VA.

Neily et al.33 showed wrong site surgery data (wrong patient, wrong side, wrong site, wrong procedure, wrong implant) stratified by occurrence before any directive (before January 2003), after the directive for operating room cases only (January to June 2004) and the updated directive Ensuring Correct Surgery and Invasive Procedures (applicable after June 2004). The graphs did not show a reduction in event associated with the directives, but showed instead that in particular reporting of close calls increased after implementing the directives (numerical numbers not reported). A followup publication in 2011^34^ showed that the rate of reported adverse events decreased from 3.21 to 2.4 per months (p<0.02) between 2001 and 2009; in addition, a medical team training program had been implemented nationally between 2006 and 2009. The reporting of close calls increased statistically significantly from 1.97 to 3.24 per month (p<0.001).

A third VA study155 reported on an approach to share lessons learned through quarterly surgery adverse event reports and surgery root cause analysis lessons. A survey showed that 75% of respondents stated that they gained new knowledge to prevent incorrect surgery. Finally, a recently published study by Paull et al.144 showed that simulated thoracentesis with variable scenarios designed to test teamwork and communication in preventing or catching errors before they cause harm to patients increases self-reported confidence in ensuring correct surgery and invasive procedures.

#### Strength of Evidence: Effectiveness of Interventions for the Prevention of Wrong Site Surgery

We identified 49 published evaluations of wrong site surgery prevention approaches. Evaluated interventions were very diverse ranging from evaluations of the Universal Protocol, individual components of the Universal Protocol, briefings and the use of checklists, team training and educational approaches, as well as equipment-related changes, or other unique approaches.

Only the Universal Protocol was evaluated in more than one study, studies provided data for followup periods of more than two years, and reported on wrong site surgery incidents together with a denominator. One of the studies48 reported a statistically significant reduction. No other intervention was evaluated in more than one study, with studies reporting on a concurrent or historic comparator, a followup period of at least two years or 50,000 observations, and reporting on the outcome of interest.

Based on the available evidence, in particular the lack of replication, study designs, followup periods, lack of reported denominators, and reported outcomes, the existing evidence base regarding interventions to prevent wrong site surgery is low with the exception of the Universal Protocol. For the latter, the strength of evidence is classified as moderate. However, the intervention was only evaluated through secular changes and other factors may have contributed to the effect and statistically significant effects were only seen in one study. Future research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.

### Interventions to Prevent Retained Surgical Items

We identified 14 publications reporting on 15 intervention studies aiming to prevent retained surgical items. One study reported on data after implementing a sponge counting protocol and after implementing a radiofrequency detection system to track surgical sponges.67 The evaluations are summarized in the evidence table.

Table 13 Evidence Table Intervention Evaluation Retained Surgical Items

ID | Country, setting/surgery | Design N F/u | Intervention focus | Intervention components | Compliance | Other/intervention-specific outcomes | AE | Effect on near misses | Effect on event incidents
| | | Counting/imagine protocol
No author, 2007^156^ | US, academic medical center | Pre-post N=n/a F/u: 2 years | Count practices | Standardization of best practices for count and count verification (what to count, when to count, procedure for incorrect count, documentation); noncompliant clinicians followed up; distraction management; required time-out when any staff member feels situation in room is unsafe (e.g., when delegating tasks); position statement on prioritizing tasks and handling interruptions; introduction of appropriately assertive communication methods; minimizing frequent policy changes | Quarterly audits, data n/a | n/a | n/a | n/a | 8 events in 18 mos before, 0 events two years after intervention
No author, 2009 157 | US, academic medical center | Pre-post N=n/a F/u: > 1 year | Count protocol | Printed checklist verified and signed by attending surgeon; unreconciled list triggers freeze for all OR personnel while surgeon and radiologist read films; each team member responsible for a set of items in OR. | n/a | Checklist documentation can be used for near miss analysis | n/a | n/a | 0 unintentionally retained objects for > 1 year”
Hunter, 2010^65^ | US, academic medical center | Post only N=1,034 surgeries per month F/up: 11 mos | X-ray protocol | Criteria for obtaining intraoperative x-rays specified (BMI >35, emergency procedure, actual procedure different from scheduled, accurate count not possible, count discrepancy); responsibility for RFI shared between radiologist and operating team; detailed form for radiology when RFI is suspected; reference guide for radiologists; radiology report communicated to physician before pt leaves OR; documentation | 21% in the beginning, later 71% | Quick identification of RFI on radiographs | n/a | n/a | 2/11,374 sentinel cases of RFIs in 11 months after implementation
Lutgendorf, 2011^72^ | US, armed forces health system, academic obstetrics practice | Pre post N=10,500 deliveries (post) F/u: 2 years | Count and x-ray protocol to reduce occurrence of retained sponges after vaginal delivery; versus vaginal sweep | Developed by multidisciplinary team; sponge count before and after all vaginal deliveries; provider to initiate sponge counts, nurses verify and document counts; if count incorrect, and vaginal sweep ineffective, thorough exam and x-ray; use of larger, radiopaque sponges; sponges laid out side by side on delivery carts to facilitate counting; avoidance of sponges in vagina if possible; tail left in view at all times if placed in vagina; global training of providers and nurses | Regular audits, data n/a | Cost of protocol implementation appr. $2.50 per delivery; counts took appr. 1 min | Initial concerns of difficulty in using larger sponges and time consuming counts were unfounded as implementation occurred | n/a | Rate of 1/5,000 deliveries with event (sponges) in 5 years with vaginal sweep, 0/10,500 deliveries in 2 years after new protocol implemented
McIntyre, 2010^66^ | US, academic medical center | Pre-post N=about 12,000 surgical procedures per year F/u: 18 mos | Count and x-ray policy | X-ray after any procedure in which body cavity is opened or wound is considered large enough to retain instrument or sponge; film obtained regardless of whether final closure has occurred, packing left, or additional surgery planned; x-ray must cover entire surgical field, interpreted by senior level resident or attending, relief counts must occur before change of personnel; baseline sponge counts mandatory, communication of packing or removal of packing; if abdominal cavity is explored landmarks from diaphragm to symphysis must be visualized; staff tutorial | n/a | Cost of routine surveillance films: $63,825 for 990 films | n/a | n/a | 3 cases in two years before all policy changes were implemented, 0 cases in 18 mos since implementation
Rupp, 2012^67^ | US, academic health system | Pre-post N=n/a F/u: n/a | Count protocol | Sponge ACCOUNTing System; several structural elements, medical personnel training, equipment (e.g., sponge holder racks) to facilitate accurate accounting of soft goods/sponges | n/a | inexpensive | n/a | n/a | 1 retained item per 36,000 operation before implementation, 1/54,000 after
| | | Team training
Cima, 2009^158^ | US, academic medical center | Pre-post N=50,000 operations annually F/u: 2 years | Conscientious Count Campaign | Phase I: defect analysis; tools collaboratively designed; Phase II: awareness and communication, mandatory meeting for all OR personnel; team communication and education, videos and printed materials, team training simulation, in-room audits with feedback, standardized counting process; “Red Rules” (inviolable OR rules, Universal Protocol, Correct Count Process followed); Phase III: monitoring and control, rapid response event team formed to deal with events within 24-36 hours to provide real time feedback, non-punitive approach to errors | 99.4% compliance in 3rd quarter in daily random audits of baseline count, tucked item documentation, and final counts | Defect per million opportunities analysis shows decline from 0.52 to 0.11 per 1,000 surgeries; increase in Sigma performance level of 5.6 to 6.0. | n/a | RFI or near miss from 1 every 16 days to 1 every 69 days | RFI or near miss from 1 every 16 days prior to intervention to 1 every 69 days sustained for 2 years
Johnson, 2012^142^ | US, community health system | Pre-post N=n/a F/u: 1 year | Pt safety course to create a culture of safety | Crew Resource Management, TeamSTEPPS, communication techniques; video vignettes featuring coworkers, audience response system to engage learners and promote participation, mandatory attendance; SBAR, callout and check back technique | Nearly all intended participants | n/a | n/a | n/a | During the year before course implementation, 12 root cause analysis requiring events (e.g., retained item, fire); 4 in the year after
Ricci, 2012^145^ | US, academic health system | Pre-post N=517 team members, 19,000 cases performed annually F/u: 2 years | Crew Resource Management program | System of effective teamwork, open communication, and optimized decision making in high-risk environments applying aviation techniques; initial 6-h training program (education, case-study discussions, team building exercises etc.), mandatory for all OR personnel; tools (checklists, feedback mechanisms) emphasis on communication (e.g., using the names of team members) and shared expectations during and at end of procedure; refresher courses planned | Compliance with local “time-out” policy increased from 6.7% to 99% 4 mos after training | Malpractice payout 4 years before: $793,000, after: $0 | n/a | n/a | Annual wrong site surgery and RFI events ranged from 3 (0.016) to 7 (0.037) in 3 years before implementation; first 14 mos after: 0 events, second year: 5 events (0.026)
| | | Equipment
Cima, 2011 61 | US, academic medical center | Pre-post N=87,404 operations (post) F/u: 18 mos | Data-matrix coded sponge (DMS) system | System includes a wide variety of labeled cotton surgical sponge products; each item has a unique data-matrix tag; bulk scanning in, each sponge must be scanned out at end of procedure | n/a | Count time decreased with repetition; 82% feel comfortable with DMS process | Additional $11.63 average cost per case by using DMS system, longer count time vs. manual (11.4 vs. 4.0 seconds); only 59% rate the DMS process as very efficient | 3 incorrect manual counts caught | 0/87,404 retained sponges over 18 mos study period, compared to retained sponge every 64 days prior; significant change in event frequency (p<0.001)
Greenberg, 2008^64^ | US, academic medical center, general surgery | RCT N=56 OR staff, 36 surgeons; control: n=148 operations intervention: n=150 operations F/u: 60 days | Bar coding surgical sponges versus traditional counting protocol | Control group: standard Peri-Operative Registered Nurses protocol for counting instruments and sponges, simultaneous manual count by ST and circulator, and written record; when removed from sterile field, sponges were counted and placed in sterile bags with 10 sponges per bag, count manually performed by both ST and RN Intervention: same as control with addition of SurgiCount Medical; sponges scanned when placed on sterile field and counted; when removed from sterile field scanned again and counted before being placed into bags by RN; concurrent counts with ST in bar code arm were not required | 44% of personnel answered end of study surveys | Detection of sponge discrepancy: 13 (control) vs 32 (intervention), p=0.008; retained or misplaced sponges: 12 vs 21 p=0.17; miscount s: 1 vs 11 p=0.007; cases with sponge discrepancy: 12 vs 24 p=0.049; cases with retained or misplaced sponge: 11 vs 17 p=0.32; confidence in ability to track sponges: 7.5, SD 7.3 on scale from 1 to 10 | 17 technological difficulties (background scanning, scanning out while scanner set to scanning in, bar code abandoned in 5/150 operations due to time constraints); mean time to resolve discrepancy: 12.7 (control) vs 13 min (intervention) p=0.61; total time counting: 8.6 vs 12 min, p<0.0001; sponge counting: 2.4 vs 5.3 min, p<0.0001 | 3 retained sponges found before pt left OR in bar code group | 0 retained sponges in both groups at 60 days of f/u
Pelter, 2007^159^ | US, community medical center, elective surgical procedures | Controlled trial N=50 pts, 16 OR personnel surveyed F/u: n/a | Numbered surgical sponges | Sequentially numbered surgical sponge product to improve ease of counting compared to routine sponge counting | n/a | Count time: 44 sec (control) vs 28 sec (intervention) p=0.098; length of procedure: 72 vs 65 mins (p=0.633); ease of use: 81% respondents agreed; 94% thought sponges are safe to use, 38% thought product would increase pt safety; 44% felt more confident with count | n/a | n/a | n/a
Rupp, 2012^67^ | US, academic health system | Pre-post N=2,285 pts (post) F/u: 10 mos study period, mean f/u 20 mos | Radiofrequency detection system | RF Surgical Systems Inc. incorporated adjunct to standard sponge-counting algorithm including Sponge ACCOUNTing System; RFDS tagged sponges; RF wand; staff training, flow diagrams of protocols, educational materials, assessment and feedback | n/a | 35 miscounts (1.53%); increased cost by $13.54 per case | n/a | 1 near miss detected with RFDS (in drapes; routine protocol did not detect it) | 0 retained items in 2,285 pts, prior to implementation the rate was 1 event per 54,000 operations
| | | Other
Neily, 2012^87^ | US, VA | Post only N=132 F/u: 2 years | Education | Sharing of lessons learned through quarterly surgery adverse events reports and surgery root cause analysis lessons | 76% of respondents had seen surgical lessons that were shared | 60% felt their facility is less likely to incur an RSI due to participation in Surgical Lessons Learned | n/a | n/a | n/a
Vannucci, 2012^69,160^ | US, academic medical center, CV catheter placement | Pre-post N=n/a F/u: n/a | Education, checklist | Multidisciplinary root cause analyses, mandatory training for new hospital interns, CVC checklist to guide and document every placement; further system changes | n/a | n/a | n/a | n/a | Retained guidewires have decreased since introducing the catheter and guidewire skills module

Notes: AE: adverse events associated with intervention; appr.: approximately; CVC: central venous catheter; ID: identification; min: minutes; N: number of patients, participants, or procedures; OR: operating room; pt: patient; RF: radiofrequency; RFI: retained foreign item; RN: registered nurse; sec: seconds; ST: surgical technologist; vs: versus

Six studies reported their experiences with implementing sponge or instrument count and/or imaging protocols. The protocols outlined the count procedure (e.g., what should be counted and when), specified responsibilities for various team members, and provided guidelines when x-rays should be taken to ensure that no item was left behind. All reported improvements but only four indicated there were no incidents between one and two years after the intervention implementation.36,66,72,157 Most protocols were developed at the organization but one study67 reported a reduction from 1/36,000 to 1/54,000 after implementing the standardized Sponge ACCOUNTing System.

We identified three team training approaches aiming to prevent retained surgical items. One was a multifaceted and multi-disciplinary campaign exclusively designed to reduce retained foreign objects which resulted in a significant and sustained reduction in incidents in a pre-post analysis.158 Johnson's142 patient safety course showed that the number of root cause analysis requiring events was reduced but it did not specifically report on the included retained surgical items. A third educational intervention applied aviation safety techniques to surgery (Crew Resource Management Program) and did also only report on a composite outcome of wrong site surgery and/or retained item incidents.

Four studies evaluated equipment-associated innovations. An RCT by Greenberg et al.64 comparing bar coding technology with the standard Peri-Operative Registered Nurses protocol reported no retained sponges in either group (N=300) but noted that the system was useful to detect miscounted and misplaced sponges. Cima et al. (2011)61 reported that a data-matrix-coded sponge counting system has eliminated sponge retained surgical items based on experiences in an 18-month period with 87,404 procedures (compared to before implementation where a retained sponge occurred on average every 64 days). The results represent a statistically significant reduction in event frequency. Rupp et al.67 reported that no items were retained in 2,285 patients when changing to a radiofrequency detection system; the rate was 1/54,000 prior to the intervention implementation when only the Sponge ACCOUNTing System was used. The numbered sponge evaluation did not report on incidents but noted that staff felt more confident with the product.159

#### VA Subgroup Analysis: Effectiveness of Interventions for the Prevention of Retained Surgical Items

One VA study was identified. Neily et al.155 reported on an educational intervention through quarterly surgery adverse events reports and surgery root cause analyses and reported that 60% felt their facility is less likely to incur a retained surgical item due to participation in “Surgical Lessons Learned” but no incidence data were presented.

#### Strength of Evidence: Effectiveness of Interventions for the Prevention of Retained Surgical Items

We identified 15 evaluations, including one RCT evaluating interventions for the prevention of retained items. However, only one of the studies (using a data-matrix-coded sponge counting system) demonstrated a statistical significant effect of the intervention compared to a concurrent or historic comparator.61 Our knowledge about the comparative effectiveness of different approaches to prevent retained surgical items is very limited. Given the rare event that is studied, analyses with longer follow-up periods may change our current knowledge.

### Interventions to Prevent Surgical Fires

We identified eight studies evaluating interventions to prevent surgical fires. The studies are summarized in the evidence table, broadly categorized by approach (education, equipment, other).

Table 14 Evidence Table Intervention Evaluation Surgical Fires

ID | Country, setting/surgery | Design N F/u | Intervention focus | Intervention components | Compliance | Other/intervention-specific outcomes | AE | Effect on near misses | Effect on event incidents
| | | Education
Flowers, 2004^161^ | US, community medical center | Post only N=n/a F/u: n/a | OR fire drill, new fire safety plan | OR-based fire scenarios, roll-play activities | n/a | Self-reported improved confidence in handling OR fires, improved knowledge of location and use of fire suppression devices | Communication difficulties associated with knowledge that drill was not real | n/a | n/a
Galvagno, 2009^162^ | US, academic anesth. program | Pre-post N=29 anesth. residents F/u: 9 mos course | Critical action procedure education | Administration of critical action procedure tests (including airway fire) to improve knowledge about how to respond to rare and potentially catastrophic events | 18/29 completed test | Percent of correct response in airway fire test scores increased from 20 to 80%; 90% agreed it was a worthwhile learning experience | n/a | n/a | n/a
Lypson, 2005^112^ | US, academic medical center | Pre-post N=152 interns F/u: n/a | Fire safety education | Training station with video education, surgical fire brochure, and multiple choice test | n/a | 61% unaware of risk of surgical fires prior to education and 87% felt they would know how to prevent surgical fires after education | n/a | n/a | n/a
| | | Equipment
Lunn, 2005 163 | US, academic medical center | Post only N=23 pts F/u: 1-24 months | Microdebrider bronchoscopy | Metal tube attached to suction with oscillating tracheal blade; avoids need for laser or electrocautery devices | n/a | n/a | 1 pt required admission for dyspnea, found to have undiagnosed bilateral vocal cord paresis | n/a | 0/23 complications such as airway fires
Militana, 2007^164^ | US, academic medical center | Post only N=25 pts F/u: n/a | Use of laryngeal mask airway | Use of laryngeal mask airway to prevent airway fires | 100% | n/a | 1 pt needed different size to achieve adequate airway seal | n/a | 0/25 airway fires despite use of electrocautery
Rezaie-Majd, 2006^165^ | Austria, academic medical center | Post only N=1,515 pts F/u: 1990-2004 | Superimposed high-frequency jet ventilation | Designed for laryngotracheal surgery, two jet streams with different frequencies applied simultaneously; avoids tracheal tubes or catheters | n/a | Adequate oxygenation and ventilation achieved in 1,512 pts | No major hemorrhage, or aspiration of debris | n/a | 0/1,515 airway fires
| | | Other
Johnson, 2012^142^ | US, community health system | Pre-post N=n/a F/u: 1 year | Pt safety course to create a culture of safety | Crew Resource Management, TeamSTEPPS, communication techniques; video vignettes featuring coworkers, audience response system to engage learners and promote participation, mandatory attendance; SBAR, callout and check back technique | Nearly all intended participants | n/a | n/a | n/a | Pre: 12 root cause analysis requiring events in 1 year (e.g., retained item, fire), post: 4 in 1 year
Mathias, 2006,^166^, Williams, 2008^167^ | US, community health care system | Pre-post N=n/a F/u=n/a | Scoring system to identify intraoperative fire risk; OR fire drills | Assessment of elements of fire triangle: incision over the xiphoid process, open oxygen source, available ignition source. Protocols for all OR providers based on fire risk score; yearly OR fire drills | n/a | Communication among surgical team members and identification of the fire risk triangle improved | n/a | n/a | No significant fire or injury to a pt due to fire since implementation, 2 fires before but study periods not specified

Note: AE: adverse event associated with intervention; anesth.: anesthesia; F/u: Follow up; N: number of patients, participants, or procedures; OR: operating room; SBAR: situation, background, assessment and recommendation

Three educational interventions such as fire drills were evaluated. All reported improvements in provider knowledge; however, no data on the effect of fire incidents was presented.

Of three equipment-related studies, two interventions reported on experiences with two anesthesia techniques: use of laryngeal mask airway and superimposed high-frequency jet ventilation for laryngotracheal surgery. Both reported that no airway fires occurred but only the jet ventilation study reported on a substantial sample (N=1,515) and a 14 year followup period. One study tested a bronchoscopy tool and found no complications such as airway fires; however, the sample was limited to 23 patients.163

One identified intervention142 evaluated the effect of a patient safety course to create a culture of safety on serious events that would require a root cause analysis according to the Joint Commission but did not specify which events occurred. One institution developed a fire risk assessment system used for every patient and announced by the circulating nurse during the time out before surgery begins in combination with yearly fire drills. No significant fire or injury to a patient due to fire occurred since its implementation; however, the followup period was not specified.166,167

#### VA Subgroup Analysis: Effectiveness of Interventions for the Prevention of Surgical Fires

We did not identify a study evaluating fire prevention interventions in a VA facility.

#### Strength of Evidence: Effectiveness of Interventions for the Prevention of Surgical Fires

Given the limitations of study design (primarily post-only) and insufficient followup periods for all but one study, and the limited outcomes utilized in most studies, the quality of the evidence is very low.