# REFERENCES

1 Bani-Hani KE, Gharaibeh KA, Yaghan RJ. Retained surgical sponges (gossypiboma). Asian J Surg. Apr. 2005;28(2):109-115. [pmid: 15851364].
2 Levy DA. No defense for wrong-site surgery. AAOS Bull. 1998;46:18.
3 Dunn D. Surgical site verification: A through Z. Journal of PeriAnesthesia Nursing. 2006;21(5):317-331. [pmid: 17027441].
4 Biswas RS, Ganguly S, Saha ML, Saha S, Mukherjee S, Ayaz A. Gossypiboma and Surgeon - Current Medicolegal Aspect - A Review. Indian Journal of Surgery. Aug. 2012;74(4):318-322. [pmid: 23904722].
5 Daane SP, Toth BA. Fire in the operating room: principles and prevention. Plast Reconstr Surg. Apr. 15. 2005;115(5):73e-75e.
6 National Quality Forum (NQF). Serious Reportable Events In Healthcare— 2011 Update: A Consensus Report. Available at: http://www.qualityforum.org/Publications/2011/12/Serious_Reportable_Events_in_Healthcare_2011.aspx. Washington DC. NQF. 2011.
7 The Joint Commission. Sentinel Event Alert. Lessons Learned: Wrong Site Surgery. Available at: http://www.jointcommission.org/assets/1/18/SEA_6.pdf. August. 28. 1998;(6).
8 The Joint Commission. Sentinel Event Alert. Preventing surgical fires. Available at: http://www.jointcommission.org/assets/1/18/SEA_29.PDF. June. 24. 2003;(29).
9 The Joint Commission. Sentinel Events (SE). 2012. http://www.jointcommission.org/assets/1/6/2011_CAMH_SE.pdf. February, 18, 2013.
10 Whang G, Mogel GT, Tsai J, Palmer SL. Left behind: unintentionally retained surgically placed foreign bodies and how to reduce their incidence--self-assessment module. AJR. American journal of roentgenology. Dec. 2009;193(6 Suppl):S90-93. [pmid: 19933681].
11 Gawande AA, Studdert DM, Orav EJ, Brennan TA, Zinner MJ. Risk factors for retained instruments and sponges after surgery. N Engl J Med. Jan. 16. 2003;348(3):229-235. [pmid: 12529464].
12 Chung KC, Kotsis SV. Complications in surgery: Root cause analysis and preventive measures. Plastic and Reconstructive Surgery. 2012;129(6):1421-1427. [pmid: 22634659].
13 Wrong-site surgery: we're not all that we can. Healthcare Benchmarks Qual Improv. Jun. 2008;15(6):49-52. [pmid: 18678178].
14 Raval MV, Weiner TM. Beware of the flaming hairball--a brief review and warning. J Pediatr Surg. Apr. 2005;40(4):E37-38. [pmid: 15852262].
15 Macdonald AG. A brief historical review of non-anaesthetic causes of fires and explosions in the operating room. Br J Anaesth. Dec. 1994;73(6):847-856. [pmid: 7880680].
16 Bayley G, McIndoe AK. Fires and explosions. Anaesthesia and Intensive Care Medicine. 2004;5(11):364-366.
17 Carney BL. Evolution of wrong site surgery prevention strategies. AORN J. May. 2006;83(5):1115-1118. 1121. 1112. [pmid: 16722287].
18 Eldridge N. Ensuring Correct Surgery and Invasive Procedures. Topics in Patient Safety. Sept/Oct. 2004;4(4):1. http://www.patientsafety.gov/TIPS/Docs/TIPS_SeptOct04.pdf.
19 Ulucay T, Dizdar MG, SunayYavuz M, Asirdizer M. The importance of medico-legal evaluation in a case with intraabdominal gossypiboma. Forensic Sci Int. May. 20. 2010;198(1-3):e15-18. [pmid: 20163926].
20 Recommended practices for sponge, sharp, and instrument counts. AORN Recommended Practices Committee. Association of periOperative Registered Nurses. AORN J. Dec. 1999;70(6):1083-1089. [pmid: 10635432].
21 Barrett SL, Vella JM, Dellon AL. Historical development of bipolar coagulation. Microsurgery. Nov. 2010;30(8):667-669. [pmid: 20842704].
22 Nishiyama K, Komori M, Kodaka M, Tomizawa Y. Crisis in the operating room: fires, explosions and electrical accidents. J Artif Organs. Sep. 2010;13(3):129-133. [pmid: 20711622].
23 Watson DS. Surgical fires: 100% preventable, still a problem. AORN J. Oct. 2009;90(4):589-593. [pmid: 19801014].
24 Pierce JS, Lacey SE, Lippert JF, Lopez R, Franke JE, Colvard MD. An assessment of the occupational hazards related to medical lasers. J Occup Environ Med. Nov. 2011;53(11):1302-1309. [pmid: 22027542].
25 New Joint Commission center to take on wrong-site surgery. OR Manager. Nov. 2009;25(11):1. 6.
26 Asiyanbola B, Etienne-Cummings R, Lewi JS. Prevention and diagnosis of retained foreign bodies through the years: past, present, and future technologies. Technol Health Care. 2012;20(5):379-386. [pmid: 23079943].
27 Paugh DH, White KW. Fire in the operating room during tracheotomy: a case report. AANA J. Apr. 2005;73(2):97-100. [pmid: 15835828].
28 A team approach to surgical fire prevention. Understanding the fire triangle. Health Devices. Feb. 2006;35(2):49-53. 55. 47. [pmid: 16541833].
29 Cima RR, Hale C, Kollengode A, Rogers JC, Cassivi SD, Deschamps C. Surgical case listing accuracy: failure analysis at a high-volume academic medical center. Arch Surg. Jul. 2010;145(7):641-646. [pmid: 20644126].
30 Knight N, Aucar J. Use of an anatomic marking form as an alternative to the Universal Protocol for Preventing Wrong Site, Wrong Procedure and Wrong Person Surgery. Am J Surg. Dec. 2010;200(6):803-807. discussion 807-809. [pmid: 21146024].
31 Kwaan MR, Studdert DM, Zinner MJ, Gawande AA. Incidence, patterns, and prevention of wrong-site surgery. Arch Surg. Apr. 2006;141(4):353-357. discussion 357-358. [pmid: 16618892].
32 Mulloy DF. Evaluation of implementation of the AORN Correct Site Surgery Tool Kit and the Universal Protocol for wrong site surgery. University of Massachusetts Boston. 2008;166.
33 Neily J, Mills PD, Eldridge N, et al. Incorrect surgical procedures within and outside of the operating room. Arch Surg. Nov. 2009;144(11):1028-1034. [pmid: 19917939].
34 Neily J, Mills PD, Eldridge N, et al. Incorrect surgical procedures within and outside of the operating room: a follow-up report. Arch Surg. Nov. 2011;146(11):1235-1239. [pmid: 21768408].
35 Wu RL, Aufses AH. Characteristics and costs of surgical scheduling errors. American Journal of Surgery. Oct. 2012;204(4):468-473. [pmid: 23010615].
36 Clarke JR, Johnston J, Finley ED. Getting surgery right. Ann Surg. Sep. 2007;246(3):395-403. discussion 403-395. [pmid: 17717443].
37 Faltz LL, Morley JN, Flink E, Dameron PDH. The New York Model: Root Cause Analysis Driving Patient Safety Initiative to Ensure Correct Surgical and Invasive Procedures Assessment). Aug. 2008.
38 Griffen FD, Stephens LS, Alexander JB, et al. The American College of Surgeons' Closed Claims Study: New Insights for Improving Care. Journal of the American College of Surgeons. 2007;204(4):561-569. [pmid: 17382214].
39 Mehtsun WT, Ibrahim AM, Diener-West M, Pronovost PJ, Makary MA. Surgical never events in the United States. Surgery. Dec. 17. 2012.
40 Stahel PF, Sabel AL, Victoroff MS, et al. Wrong-site and wrong-patient procedures in the Universal Protocol era: analysis of a prospective database of physician self-reported occurrences. Arch Surg. Oct. 2010;145(10):978-984. [pmid: 20956767].
41 Adetayo OA, Salcedo SE, Biskup NI, Gupta SC. The battle of words and the reality of never events in breast reconstruction: incidence, risk factors predictive of occurrence, and economic cost analysis. Plast Reconstr Surg. Jul. 2012;130(1):23-29. [pmid: 22743870].
42 James MA, Seiler JG 3rd, Harrast JJ, Emery SE, Hurwitz S. The occurrence of wrong-site surgery self-reported by candidates for certification by the American Board of Orthopaedic Surgery. J Bone Joint Surg Am. Jan. 4. 2012;94(1):e2. (1-12). [pmid: 22218388].
43 Jin GJ, Crandall AS, Jones JJ. Intraocular lens exchange due to incorrect lens power. Ophthalmology. Mar. 2007;114(3):417-424. [pmid: 17123608].
44 Lee JS, Curley AW, Smith RA. Prevention of wrong-site tooth extraction: clinical guidelines. J Oral Maxillofac Surg. Sep. 2007;65(9):1793-1799. [pmid: 17719400].
45 Mody MG, Nourbakhsh A, Stahl DL, Gibbs M, Alfawareh M, Garges KJ. The prevalence of wrong level surgery among spine surgeons. Spine. Jan. 15. 2008;33(2):194-198. [pmid: 18197106].
46 Shen E, Porco T, Rutar T. Errors in strabismus surgery. Archives of Ophthalmology. 2013;131(1):75-79.
47 Simon JW. Preventing surgical confusions in ophthalmology (an American Ophthalmological Society thesis). Trans Am Ophthalmol Soc. 2007;105:513-529. [pmid: 18427628].
48 Vachhani JA, Klopfenstein JD. Incidence of Neurosurgical Wrong Site Surgery Before and After Implementation of the Universal Protocol. Neurosurgery. Dec. 20. 2012.
49 Fager CA. Malpractice issues in neurological surgery. Surgical neurology. 2006;65(4):416. [pmid: 16531218].
50 Groff MW, Heller JE, Potts EA, Mummaneni PV, Shaffrey CI, Smith JS. A Survey-Based Study of Wrong-Level Lumbar Spine Surgery: The Scope of the Problem and Current Practices in Place to Help Avoid These Errors. World Neurosurg. Apr. 2. 2012.
51 Kelly JJ, Farley H, O'Cain C, et al. A survey of the use of time-out protocols in emergency medicine. Jt Comm J Qual Patient Saf. Jun. 2011;37(6):285-288. [pmid: 21706988].
52 Perlis CS, Campbell RM, Perlis RH, Malik M, Dufresne RG Jr. Incidence of and risk factors for medical malpractice lawsuits among Mohs surgeons. Dermatol Surg. Jan. 2006;32(1):79-83. [pmid: 16393602].
53 Schweitzer KM Jr, Brimmo O, May R, Parekh SG. Incidence of wrong-site surgery among foot and ankle surgeons. Foot Ankle Spec. Feb. 2011;4(1):10-13. [pmid: 20935072].
54 Shah RK, Nussenbaum B, Kienstra M, et al. Wrong-site sinus surgery in otolaryngology. Otolaryngol Head Neck Surg. Jul. 2010;143(1):37-41. [pmid: 20620617].
55 Shah RK, Arjmand E, Roberson DW, Deutsch E, Derkay C. Variation in surgical time-out and site marking within pediatric otolaryngology. Arch Otolaryngol Head Neck Surg. Jan. 2011;137(1):69-73. [pmid: 21242550].
56 Wong DA, Herndon JH, Canale ST, et al. Medical errors in orthopaedics. Results of an AAOS member survey. J Bone Joint Surg Am. Mar. 1. 2009;91(3):547-557. [pmid: 19255214].
57 Simon JW, Ngo Y, Khan S, Strogatz D. Surgical confusions in ophthalmology. Arch Ophthalmol. Nov. 2007;125(11):1515-1522. [pmid: 17998513].
58 Camp M, Chang DC, Zhang Y, Chrouser K, Colombani PM, Abdullah F. Risk factors and outcomes for foreign body left during a procedure: analysis of 413 incidents after 1 946 831 operations in children. Archives of Surgery. 2010;145(11):1085-1090. [pmid: 21079097].
59 Chen Q, Rosen AK, Cevasco M, Shin M, Itani KM, Borzecki AM. Detecting patient safety indicators: How valid is “foreign body left during procedure” in the Veterans Health Administration?. J Am Coll Surg. Jun. 2011;212(6):977-983. [pmid: 21489830].
60 Cima RR, Kollengode A, Garnatz J, Storsveen A, Weisbrod C, Deschamps C. Incidence and characteristics of potential and actual retained foreign object events in surgical patients. J Am Coll Surg. Jul. 2008;207(1):80-87. [pmid: 18589366].
61 Cima RR, Kollengode A, Clark J, et al. Using a data-matrix-coded sponge counting system across a surgical practice: Impact after 18 months. Joint Commission Journal on Quality and Patient Safety. 2011;37(2):51-53AP. [pmid: 21939132].
62 Egorova NN, Moskowitz A, Gelijns A, et al. Managing the prevention of retained surgical instruments: what is the value of counting?. Ann Surg. Jan. 2008;247(1):13-18. [pmid: 18156916].
63 Greenberg CC, Regenbogen SE, Lipsitz SR, Diaz-Flores R, Gawande AA. The frequency and significance of discrepancies in the surgical count. Annals of Surgery. 2008;248(2):337-341. [pmid: 18650646].
64 Greenberg CC, Diaz-Flores R, Lipsitz SR, et al. Bar-coding surgical sponges to improve safety: A randomized controlled trial. Annals of Surgery. 2008;247(4):612-616. [pmid: 18362623].
65 Hunter TB, Gimber LH. Identification of retained surgical foreign objects: policy at a university medical center. J Am Coll Radiol. Sep. 2010;7(9):736-738. [pmid: 20816639].
66 McIntyre LK, Jurkovich GJ, Gunn ML, Maier RV. Gossypiboma: tales of lost sponges and lessons learned. Arch Surg. Aug. 2010;145(8):770-775. [pmid: 20713930].
67 Rupp CC, Kagarise MJ, Nelson SM, et al. Effectiveness of a radiofrequency detection system as an adjunct to manual counting protocols for tracking surgical sponges: a prospective trial of 2,285 patients. J Am Coll Surg. Oct. 2012;215(4):524-533. [pmid: 22770865].
68 Stawicki SP, Moffatt-Bruce SD, Ahmed HM, et al. Retained Surgical Items: A Problem Yet to Be Solved. J Am Coll Surg. Oct. 4. 2012.
69 Vannucci A, Jeffcoat A, Ifune C, Salinas C, Duncan JR, Wall M. Retained Guidewires After Intraoperative Placement of Central Venous Catheters. Anesth Analg. Jun. 5. 2012.
70 Lincourt AE, Harrell A, Cristiano J, Sechrist C, Kercher K, Heniford BT. Retained foreign bodies after surgery. J Surg Res. Apr. 2007;138(2):170-174. [pmid: 17275034].
71 Samples C. Reducing the Vulnerability of Retained Surgical Sponges. Topics in Patient Safety. 2004;4(4):2-3. http://www.patientsafety.gov/TIPS/Dpcs/TIPS_SeptOct04.pdf.
72 Lutgendorf MA, Schindler LL, Hill JB, Magann EF, O'Boyle JD. Implementation of a protocol to reduce occurrence of retained sponges after vaginal delivery. Mil Med. Jun. 2011;176(6):702-704. [pmid: 21702393].
73 Morse BC, Boland BN, Blackhurst DW, Roettger RH. Analysis of Centers for Medicaid and Medicare Services ‘never events’ in elderly patients undergoing bowel operations. Am Surg. Aug. 2010;76(8):841-845. [pmid: 20726414].
74 Teixeira PG, Inaba K, Salim A, et al. Retained foreign bodies after emergent trauma surgery: incidence after 2526 cavitary explorations. Am Surg. Oct. 2007;73(10):1031-1034. [pmid: 17983075].
75 Simonsen AR, Duncavage JA, Becker SS. A review of malpractice cases after tonsillectomy and adenoidectomy. Int J Pediatr Otorhinolaryngol. Sep. 2010;74(9):977-979. [pmid: 20708128].
76 Metzner J, Posner KL, Lam MS, Domino KB. Closed claims' analysis. Best Practice and Research: Clinical Anaesthesiology. 2011;25(2):263-276. [pmid: 21550550].
77 Kressin K, Posner K, Lee L. Burn injury in the operating room: a closed claims analysis. ASA Newsletter. 2004;68(6):9-11.
78 Smith LP, Roy S. Operating room fires in otolaryngology: risk factors and prevention. Am J Otolaryngol. Mar-Apr. 2011;32(2):109-114. [pmid: 20392535].
79 Clarke JR, Johnston J, Blanco M, Martindell DP. Wrong-site surgery: can we prevent it?. Adv Surg. 2008;42:13-31. [pmid: 18953807].
80 Kelly SP, Jalil A. Wrong intraocular lens implant; learning from reported patient safety incidents. Eye (Lond). Jun. 2011;25(6):730-734. [pmid: 21350567].
81 Blanco M, Clarke JR, Martindell D. Wrong site surgery near misses and actual occurrences. AORN J. Aug. 2009;90(2):215-218. 221. 212. [pmid: 19664413].
82 Cohen FL, Mendelsohn D, Bernstein M. Wrong-site craniotomy: analysis of 35 cases and systems for prevention. J Neurosurg. Sep. 2010;113(3):461-473. [pmid: 20020843].
83 Mallett R, Conroy M, Saslaw LZ, Moffatt-Bruce S. Preventing Wrong Site, Procedure, and Patient Events Using a Common Cause Analysis. American Journal of Medical Quality. Jan-Feb. 2012;27(1):21-29. [pmid: 21835810].
84 Mitchell P, Nicholson CL, Jenkins A. Side errors in neurosurgery. Acta Neurochirurgica. 2006;148(12):1289-1292. [pmid: 17075684].
85 Schein OD, Banta JT, Chen TC, Pritzker S, Schachat AP. Lessons learned: wrong intraocular lens. Ophthalmology. Oct. 2012;119(10):2059-2064. [pmid: 22704833].
86 Duthie EA. Application of human error theory in case analysis of wrong procedures. Journal of Patient Safety. 2010;6(2):108-114. [pmid: 22130353].
87 Neily J, Mills PD, Paull DE, et al. Sharing lessons learned to prevent incorrect surgery. Am Surg. Nov. 2012;78(11):1276-1280. [pmid: 23089448].
88 Learning from never events: one hospital's reaction to a wrong-site surgery. Joint Commission Perspectives on Patient Safety. 2008;8(12):8-10.
89 Knight F, Galvin R, Davoren M, Mason KP. The evolution of Universal Protocol in interventional radiology. Journal of Radiology Nursing. 2006;25(4):106-115.
90 Lee SL. The extended surgical time-out: does it improve quality and prevent wrong-site surgery?. Perm J. Spring. 2010;14(1):19-23. [pmid: 20740127].
91 Henley MJ, Rai J, Hersey N, Chilton CP. The procedure band, a simple way to prevent wrong site surgery? a 40,000 patient trial. Bju International. Jun. 2008;101:34-34.
92 Wan W, Le T, Riskin L, Macario A. Improving safety in the operating room: a systematic literature review of retained surgical sponges. Curr Opin Anaesthesiol. Apr. 2009;22(2):207-214. [pmid: 19390247].
93 Healy P. Retained vaginal swabs: review of an adverse event in obstetrics through closed claims analysis. British Journal of Midwifery. 2012;20(9):666-669.
94 Moffatt-Bruce SD, Ellison EC, Anderson HL 3rd, et al. Intravascular retained surgical items: A multicenter study of risk factors. J Surg Res. Nov. 2012;178(1):519-523. [pmid: 22516346].
95 Modrzejewski A, Kiciak A, Śledz M, et al. Migration of a foreign body into the colon and its autonomous excretion. Medical Science Monitor. 2011;17(3):16.
96 Whang G, Mogel GT, Tsai J, Palmer SL. Left behind: unintentionally retained surgically placed foreign bodies and how to reduce their incidence--pictorial review. AJR. American journal of roentgenology. Dec. 2009;193(6 Suppl):S79-89. [pmid: 19933680].
97 Gibbs VC. Retained surgical items and minimally invasive surgery. World J Surg. Jul. 2011;35(7):1532-1539. [pmid: 21431441].
98 Agrawal A. Counting matters: lessons from the root cause analysis of a retained surgical item. Jt Comm J Qual Patient Saf. Dec. 2012;38(12):566-574. [pmid: 23240265].
99 Connelly CL, Archdeacon MT. Pulsatile lavage irrigator tip, a rare radiolucent retained foreign body in the pelvis: a case report. Patient Saf Surg. 2011;5:14. [pmid: 21619681].
100 Richter GT, Willging JP. Suction cautery and electrosurgical risks in otolaryngology. Int J Pediatr Otorhinolaryngol. Jul. 2008;72(7):1013-1021. [pmid: 18439690].
101 Pierce J, Lacey S, Lopez R, Lippert J, Franke J. Contributing factors to fires in clinical settings during medical laser applications. Journal of Laser Applications. Aug. 2012;24(3).
102 Rocos B, Donaldson LJ. Alcohol skin preparation causes surgical fires. Ann R Coll Surg Engl. Mar. 2012;94(2):87-89. [pmid: 22391366].
103 Haith LR Jr, Santavasi W, Shapiro TK, et al. Burn center management of operating room fire injuries. J Burn Care Res. Sep-Oct. 2012;33(5):649-653. [pmid: 22878495].
104 Prevent surgical boom fires with routine maintenance. Health Devices. Jan. 2008;37(1):24-26. [pmid: 18771205].
105 Meltzer HS, Granville R, Aryan HE, Billman G, Bennett R, Levy ML. Gel-based surgical preparation resulting in an operating room fire during a neurosurgical procedure: case report. J Neurosurg. Apr. 2005;102(3 Suppl):347-349. [pmid: 15881765].
106 Best practices for fire prevention in perioperative settings. AORN J. Jul. 2006;84(Suppl 1):S37-44. [pmid: 16892941].
107 Kaddoum RN, Chidiac EJ, Zestos MM, Ahmed Z. Electrocautery-induced fire during adenotonsillectomy: report of two cases. J Clin Anesth. Mar. 2006;18(2):129-131. [pmid: 16563331].
108 Laudanski K, Schwab WK, Bakuzonis CW, Paulus DA. Thermal damage of the humidified ventilator circuit in the operating room: an analysis of plausible causes. Anesth Analg. Dec. 2010;111(6):1433-1436. [pmid: 20889940].
109 Beesley J, Taylor L. Reducing the risk of surgical fires: are you assessing the risk?. J Perioper Pract. Dec. 2006;16(12):591-597. [pmid: 17193998].
110 Cady RF. Operating room fires: the CRNA and the deposition. AANA J. Feb. 2007;75(1):9-11. [pmid: 17304776].
111 Herman MA, Laudanski K, Berger J. Surgical fire during organ procurement. Internet Journal of Anesthesiology. 2009;19(1).
112 Lypson ML, Stephens S, Colletti L. Preventing surgical fires: who needs to be educated?. Jt Comm J Qual Patient Saf. Sep. 2005;31(9):522-527. [pmid: 16255330].
113 Priori A, Giannicola G, Rosa M, et al. Deep brain electrophysiological recordings provide possible clues to what is wrong in Tourette syndrome. Neurosci Biobehav Rev. Jan. 16. 2013.
114 Angle JF, Nemcek AA Jr., Cohen AM, et al. Quality improvement guidelines for preventing wrong site, wrong procedure, and wrong person errors: application of the joint commission “Universal Protocol for preventing wrong site, wrong procedure, wrong person surgery” to the practice of interventional radiology. J Vasc Interv Radiol. Jul. 2009;20(7 Suppl):S256-262. [pmid: 19560005].
115 Doty S, Harder K, Clark C, et al. Health Care Protocol: Prevention of Unintentionally Retained Foreign Objects During Vaginal Deliveries. 4th ed. Bloomington. Institute for Clinical Systems Improvement (ICSI). January. 2012.
116 Sawyer M, Danielson D, Degnan B, et al. Perioperative protocol. Health care protocol. Bloomington. Institute for Clinical Systems Improvement (ICSI). Updated. November. 2012.
117 Apfelbaum JL, Caplan RA, Barker SJ, et al. Practice advisory for the prevention and management of operating room fires: an updated report by the american society of anesthesiologists task force on operating room fires. Anesthesiology. Feb. 2013;118(2):271-290. [pmid: 23287706].
118 Starling J 3rd, Coldiron BM. Outcome of 6 years of protocol use for preventing wrong site office surgery. J Am Acad Dermatol. Oct. 2011;65(4):807-810. [pmid: 21764169].
119 Ablinger P, Hackethal S, Gautschi S, Seifert B, Hegi T. No Wrong Site/Patient Surgery for 18 month after Implementation of a Checklist: Is everything all right?. Swiss Medical Weekly. Oct. 2010;140:20S-20S.
120 Bergal LM, Schwarzkopf R, Walsh M, Tejwani NC. Patient participation in surgical site marking: can this be an additional tool to help avoid wrong-site surgery?. J Patient Saf. Dec. 2010;6(4):221-225. [pmid: 21500609].
121 Butcher L. Wrong-site surgery. Hosp Health Netw. Nov. 2011;85(11):34-37. 31. [pmid: 22195444].
122 DeFontes J, Surbida S. Preoperative safety briefing project. Permanente J. 2004;8:21-27.
123 DiGiovanni CW, Kang L, Manuel J. Patient compliance in avoiding wrong-site surgery. J Bone Joint Surg Am. May. 2003;85-A(5):815-819. [pmid: 12728030].
124 Duggineni S. Wrong side surgery. Br Dent J. May. 14. 2011;210(9):396. 398. [pmid: 21566586].
125 Garnerin P, Ares M, Huchet A, Clergue F. Verifying patient identity and site of surgery: improving compliance with protocol by audit and feedback. Qual Saf Health Care. Dec. 2008;17(6):454-458. [pmid: 19064662].
126 Harrington JW. Surgical time outs in a combat zone. AORN J. Mar. 2009;89(3):535-537. [pmid: 19269378].
127 Johnston G, Ekert L, Pally E. Surgical site signing and “time out”: issues of compliance or complacence. J Bone Joint Surg Am. Nov. 2009;91(11):2577-2580. [pmid: 19884430].
128 Khoshbin A, Lingard L, Wright JG. Evaluation of preoperative and perioperative operating room briefings at the Hospital for Sick Children. Can J Surg. Aug. 2009;52(4):309-315. [pmid: 19680516].
129 Lee AJ, Raniga S, Hooper G, et al. The Time Out Procedure: have we changed our practice?. N Z Med J. Sep. 21. 2012;125(1362):26-35. [pmid: 23178602].
130 Hooper G, Darley D, Patton D, Perry A, Skelton R. Time Out: Avoiding wrong site surgery: An audit of six months experience. Journal of Bone & Joint Surgery, British Volume. 2006;88(SUPP II):311-311.
131 Leonard M, Graham S, Bonacum D. The human factor: the critical importance of effective teamwork and communication in providing safe care. Qual Saf Health Care. Oct. 2004;13(Suppl 1):i85-90. [pmid: 15465961].
132 Lyons MK. Eight-year experience with a neurosurgical checklist. American Journal of Medical Quality. 2010;25(4):285-288. [pmid: 20466879].
133 Makary MA, Mukherjee A, Sexton JB, et al. Operating room briefings and wrong-site surgery. J Am Coll Surg. Feb. 2007;204(2):236-243. [pmid: 17254927].
134 Norton EK, Rangel SJ. Implementing a Pediatric Surgical Safety Checklist in the OR and Beyond. AORN Journal. 2010;92(1):61-71. [pmid: 20619773].
135 Reid JH. Surgical Never Events should never happen. J Perioper Pract. Nov. 2011;21(11):373-378. [pmid: 22165490].
136 Wauben LSGL, Doorn CMDV, Klein J, Lange JF, Goossens RHM. Participatory design: Implementation of time out and debriefing in the operating theatre. Journal of Design Research. 2011;9(3):220-240.
137 Wood DA. Safer surgery: Hudson Valley hospitals avoid Medicare's never events, increase patient safety by focusing on OR protocols. Nursing Spectrum New York & New Jersey Edition. 2009;21(16):6-7.
138 Avoiding wrong-site surgery for 5 years isn't long enough: hospital implements tools for improvement. Same Day Surgery. 2009;33(8):83-84.
139 Chang HH, Lee JJ, Cheng SJ, et al. Effectiveness of an educational program in reducing the incidence of wrong-site tooth extraction. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Sep. 2004;98(3):288-294. [pmid: 15356465].
140 DeJohn P. Joint Commission tools to prevent wrong surgery. OR Manager. Apr. 2012;28(4):24-25.
141 Joint Commission Center for Transforming Healthcare. Reducing the Risk of Wrong Site Surgery. 2013. http://www.centerfortransforminghealthcare.org/assets/4/6/CTH_WSS_Storyboard_final_2011.pdf. 9/10/2013.
142 Johnson HL, Kimsey D. Patient Safety: Break the Silence. AORN Journal. 2012;95(5):591-601. [pmid: 22541770].
143 Logan CA, Cressey BD, Wu RY, et al. Monitoring Universal Protocol compliance through real-time clandestine observation by medical students results in performance improvement. J Surg Educ. Jan-Feb. 2012;69(1):41-46. [pmid: 22208831].
144 Paull DE, Okuda Y, Nudell T, et al. Preventing wrong-site invasive procedures outside the operating room: a thoracentesis simulation case scenario. Simulation in healthcare : journal of the Society for Simulation in Healthcare. Feb. 2013;8(1):52-60. [pmid: 22878585].
145 Ricci MA, Brumsted JR. Crew resource management: using aviation techniques to improve operating room safety. Aviat Space Environ Med. Apr. 2012;83(4):441-444. [pmid: 22462374].
146 Russell RA, Burke K, Gattis K. Implementing a Regional Anesthesia Block Nurse Team in the Perianesthesia Care Unit Increases Patient Safety and Perioperative Efficiency. Journal of PeriAnesthesia Nursing. 2013;28(1):3-10. [pmid: 23351242].
147 Zohar E, Noga Y, Davidson E, Kantor M, Fredman B. Perioperative patient safety: correct patient, correct surgery, correct side--a multifaceted, cross-organizational, interventional study. Anesth Analg. Aug. 2007;105(2):443-447. [pmid: 17646503].
148 Facility revamps safety after wrong-site surgery. Same Day Surgery. 2011:16-17.
149 Ammerman JM, Ammerman MD, Dambrosia J, Ammerman BJ. A prospective evaluation of the role for intraoperative x-ray in lumbar discectomy. Predictors of incorrect level exposure. Surgical neurology. Nov. 2006;66(5):470-473. discussion 473-474. [pmid: 17084188].
150 Asopa V, Ellis G, Shetty R. Three ways to avoid incorrect-level lumbar spine surgery. Ann R Coll Surg Engl. Jul. 2012;94(5):359. [pmid: 22943235].
151 Irace C, Corona C. How to avoid wrong-level and wrong-side errors in lumbar microdiscectomy. Journal of neurosurgery. Spine. Jun. 2010;12(6):660-665. [pmid: 20515352].
152 Ku H-L, Wang P-C, Su M-C, Liu CCH, Hwang W-Y. Application of Radio-frequency Identification in Perioperative Care. AORN Journal. 2011;94(2):158-172. [pmid: 21802543].
153 Nowitzke A, Wood M, Cooney K. Improving accuracy and reducing errors in spinal surgery-a new technique for thoracolumbar-level localization using computer-assisted image guidance. Spine Journal. 2008;8(4):597-604. [pmid: 18082459].
154 Upadhyaya CD, Wu JC, Chin CT, Balamurali G, Mummaneni PV. Avoidance of wrong-level thoracic spine surgery: intraoperative localization with preoperative percutaneous fiducial screw placement. Journal of neurosurgery. Spine. Mar. 2012;16(3):280-284. [pmid: 22054638].
155 Cronen G, Ringus V, Sigle G, Ryu J. Sterility of surgical site marking. J Bone Joint Surg Am. Oct. 2005;87(10):2193-2195. [pmid: 16203882].
156 Number of retained objects falls after count practices reinforced. OR Manager. Apr. 2007;23(4):8.
157 Ensuring no retained items is a shared responsibility. Same Day Surgery. 2009;33(9):90-91.
158 Cima RR, Kollengode A, Storsveen AS, et al. A multidisciplinary team approach to retained foreign objects. Jt Comm J Qual Patient Saf. Mar. 2009;35(3):123-132. [pmid: 19326803].
159 Pelter MM, Stephens KE, Loranger D. An Evaluation of a Numbered Surgical Sponge Product. AORN Journal. 2007;85(5):931-936. 938. 940. [pmid: 17499056].
160 Duncan JR. Creating and Evaluating a Data-Driven Curriculum for Central Venous Catheter Placement. Journal of Graduate Medical Education. 2010;2(3):389-397. [pmid: 21976088].
161 Flowers J. Code red in the OR – implementing an OR fire drill. AORN J. Apr. 2004;79(4):797-805. [pmid: 15115350].
162 Galvagno SM Jr, Segal BS. Critical action procedures testing: a novel method for test-enhanced learning. Med Educ. Dec. 2009;43(12):1182-1187. [pmid: 19930509].
163 Lunn W, Garland R, Ashiku S, Thurer RL, Feller-Kopman D, Ernst A. Microdebrider bronchoscopy: a new tool for the interventional bronchoscopist. Ann Thorac Surg. Oct. 2005;80(4):1485-1488. [pmid: 16181894].
164 Militana CJ, Ditkoff MK, Mattucci KF. Use of the laryngeal mask airway in preventing airway fires during adenoidectomies in children: a study of 25 patients. Ear Nose Throat J. Oct. 2007;86(10):621-623. [pmid: 17990685].
165 Rezaie-Majd A, Bigenzahn W, Denk DM, et al. Superimposed high-frequency jet ventilation (SHFJV) for endoscopic laryngotracheal surgery in more than 1500 patients. Br J Anaesth. May. 2006;96(5):650-659. [pmid: 16574723].
166 Mathias JM. Scoring fire risk for surgical patients. OR Manager. Jan. 2006;22(1):19-20.
167 Williams S. Fire in the OR! ORs can prevent blazes that put patients and staff at risk. NurseWeek California. 2008;21(2):28-29.
168 Devine J, Chutkan N, Norvell DC, Dettori JR. Avoiding wrong site surgery: a systematic review. Spine. Apr. 20. 2010;35(9 Suppl):S28-36. [pmid: 20407349].
169 Longo UG, Loppini M, Romeo G, Maffulli N, Denaro V. Errors of level in spinal surgery: An evidence-based systematic review. J Bone Joint Surg Br. Nov. 2012;94(11):1546-1550. [pmid: 23109637].
170 The Joint Commission. Sentinel Event Data: Event Type by Year 1995-2012. 2012. http://www.jointcommission.org/assets/1/18/Event_Type_by_Year_1995_4Q2012.pdf. May 30, 2013.
171 ECRI Institute. Surgical Fire Prevention. https://www.ecri.org/Products/Pages/Surgical_Fires.aspx?sub=Customized. 8/27/2013.
172 Yardley IE, Donaldson LJ. Surgical fires, a clear and present danger. Surgeon. Apr. 2010;8(2):87-92. [pmid: 20303889].
173 Stevens JP, Rogers SO. Communication and culture: opportunities for safer surgery. Qual Saf Health Care. Apr. 2009;18(2):91-92. [pmid: 19342520].
174 Gillespie BM, Chaboyer W, Lizzio A. Teamwork in the OR: enhancing communication through team-building interventions. ACORN: the Journal of Perioperative Nursing in Australia. 2008;21(1):18-19.
175 Sosis MB. Anesthesiologists must inform their surgical colleagues when there is a risk of an operating room fire. Anesth Analg. Nov. 2005;101(5):1564. [pmid: 16244046].
176 Pollock GS. AANA Journal course. Update for nurse anesthetists. Eliminating surgical fires: A team approach. AANA Journal. 2004;72(4):293-298. [pmid: 15354919].
177 Logan AC, Gao H, Wang C, et al. High-throughput VDJ sequencing for quantification of minimal residual disease in chronic lymphocytic leukemia and immune reconstitution assessment. Proc Natl Acad Sci U S A. Dec. 27. 2011;108(52):21194-21199. [pmid: 22160699].
178 Steelman VM, Hottel RA. Where There's Smoke, There's. AORN J. May. 2009;89(5):825-827. [pmid: 19422939].
179 Cima RR, Deschamps C. Role of the surgeon in quality and safety in the operating room environment. General Thoracic and Cardiovascular Surgery. 2013;61(1):1-8. [pmid: 22810462].
180 Cobb TK. Wrong site surgery-where are we and what is the next step?. Hand. 2012;7(2):229-232. [pmid: 23730251].
181 Panesar SS, Noble DJ, Mirza SB, et al. Can the surgical checklist reduce the risk of wrong site surgery in orthopaedics? – can the checklist help? Supporting evidence from analysis of a national patient incident reporting system. J Orthop Surg Res. 2011;6:18. [pmid: 21501466].
182 Winters BD, Gurses AP, Lehmann H, Sexton JB, Rampersad CJ, Pronovost PJ. Clinical review: Checklists - translating evidence into practice. Critical Care. 2009;13(6).
183 Berkowitz S, Marshall H, Charles A. Retained intra-abdominal surgical instruments: time to use nascent technology?. Am Surg. Nov. 2007;73(11):1083-1085. [pmid: 18092638].
184 Regenbogen SE, Greenberg CC, Resch SC, et al. Prevention of retained surgical sponges: a decision-analytic model predicting relative cost-effectiveness. Surgery. May. 2009;145(5):527-535. [pmid: 19375612].
185 Lampotang S, Gravenstein N, Paulus DA, Gravenstein D. Reducing the incidence of surgical fires: supplying nasal cannulae with sub-100% O2 gas mixtures from anesthesia machines. Anesth Analg. Nov. 2005;101(5):1407-1412. [pmid: 16244002].
186 Ersek RA. Flash fires during facial surgery. Plast Reconstr Surg. Jan. 2008;121(1):346. author reply 346-347. [pmid: 18176258].
187 Ersek RA. Flash fires during facial surgery (vol 121, pg 346, 2008). Plastic and Reconstructive Surgery. Feb. 2008;121(2):707-707.
188 Stoneham MD. Warning: Increased Risk of Surgical Fire Response. Anesthesia and Analgesia. May. 2009;108(5):1714-1714. [pmid: 19372362].
189 Rosenfield L. Flash fires during facial surgery - Reply. Plastic and Reconstructive Surgery. Jan. 2008;121(1):346-347. [pmid: 18176258].
190 New clinical guide to surgical fire prevention. Patients can catch fire--here's how to keep them safer. Health Devices. Oct. 2009;38(10):314-332. [pmid: 20853765].
191 Fire marshal bans alcohol-based preps. OR Manager. Jun. 2005;21(6):5. 7.
192 When a fire occurs… Knowing how to respond in the event of a surgical fire. Health Devices. Feb. 2006;35(2):58-63. [pmid: 16541834].
193 Pronovost PJ, Miller MR, Wachter RM. Tracking progress in patient safety: an elusive target. JAMA. Aug. 9. 2006;296(6):696-699. [pmid: 16896113].
194 Marshall MB, Emerson D. Patient Safety in the Surgical Setting. Thoracic Surgery Clinics. 2012;22(4):545-550. [pmid: 23084618].
195 Seiden SC, Barach P. Wrong-site surgeries are preventable - Reply. Archives of Surgery. Nov. 2007;142(11):1112-1112. [pmid: 18025346].
196 Lin IH, Hwang CF, Kao YF, Chang KA, Peng JP. Tracheostomal fire during an elective tracheostomy. Chang Gung Med J. Mar. 2005;28(3):186-190. [pmid: 15945326].
197 Crosby CT. Reducing surgical fire risk. Healthcare Purchasing News. 2005;29(3):32-33.
198 VA strengthens critical patient-safety procedure. Health Management Technology. 2010;31(4):28-29.
199 Zastrow SL. Adapting the JCAHO protocol for perioperative quality care. Journal of Continuing Education in Nursing. 2006;37(2):54-55. [pmid: 16883667].
200 Ohashi K, Kurihara Y, Watanabe K, Tanaka H. Safe patient transfer system with monitoring of location and vital signs. Journal of Medical and Dental Sciences. 2008;55(1):33-41. [pmid: 19845148].
201 Clarke D, Park A. Active-RFID system accuracy and its implications for clinical applications. Proceedings - IEEE Symposium on Computer-Based Medical Systems. 2006;2006:21-26.
202 Jeong BH, Cheng CY, Prabhu V, Yu BJ. An RFID Application Model For Surgery Patient Identification. Paper presented at: Advanced Management of Information for Globalized Enterprises, 2008, AMIGE 2008. IEEE Symposium on. 28-29 Sept. 2008. 2008.
203 Berendzen JA, van Nes JB, Howard BC, Zite NB. Fire in labor and delivery: simulation case scenario. Simulation in healthcare : journal of the Society for Simulation in Healthcare. Feb. 2011;6(1):55-61. [pmid: 21330851].
204 Meyer MA, Levine WC, Egan MT, et al. A computerized perioperative data integration and display system. International Journal of Computer Assisted Radiology and Surgery. 2007;2(3-4):191-202.
205 Vats A, Vincent C, Nagpal K, Davies R, Darzi A, Moorthy K. Practical challenges of introducing WHO surgical checklist: UK pilot experience. Bmj. 2010:340.
206 Mahar P, Wasiak J, Batty L, Fowler S, Cleland H, Gruen RL. Interventions for reducing wrong-site surgery and invasive procedures. Cochrane Database Syst Rev. 2012;(9). CD009404.
207 No single step prevents wrong surgery. OR Manager. Aug. 2007;23(8):7.
208 Minnesota. Department of Health. Adverse Health Events in Minnesota. 2007.
209 Bilimoria NM. CMS “never events” and other new trends in quality health care standards for hospitals. Health Care Law Mon. Dec. 2008;2008(12):2-10. [pmid: 19385444].
210 Norton EK, Martin C, Micheli AJ. Patients count on it: an initiative to reduce incorrect counts and prevent retained surgical items. AORN J. Jan. 2012;95(1):109-121. [pmid: 22201575].
211 Edmonds CR, Liguori GA, Stanton MA. Two cases of a wrong-site peripheral nerve block and a process to prevent this complication. Reg Anesth Pain Med. Jan-Feb. 2005;30(1):99-103. [pmid: 15690274].
212 Telem DA, Buch KE, Ellis S, Coakley B, Divino CM. Integration of a formalized handoff system into the surgical curriculum: resident perspectives and early results. Arch Surg. Jan. 2011;146(1):89-93. [pmid: 21242451].
213 Kranzfelder M, Zywitza D, Jell T, et al. Real-Time Monitoring for Detection of Retained Surgical Sponges and Team Motion in the Surgical Operation Room Using Radio-Frequency-Identification (RFID) Technology: A Preclinical Evaluation. Journal of Surgical Research. Jun. 2012;175(2):191-198. [pmid: 21571315].
214 Kwan A. The use of Storz bronchoscope in prevention of airway fire. Anaesth Intensive Care. Oct. 2004;32(5):720. author reply 720. [pmid: 15535504].
215 Mace S. Keeping count: “radio tags” help eliminate retained foreign bodies. NurseWeek California. 2006;19(22):14-15.
216 Norton E. Using an alternative site marking form to comply with the Universal Protocol. AORN Journal. 2011;93(5):600-606. [pmid: 21530709].
217 News briefs New device developed to prevent wrong-site surgery. Healthcare Benchmarks & Quality Improvement. 2008;15(2):23.
218 Microchip promises to reduce wrong-site errors. Healthcare Risk Management. 2005;27(4):44-45.
219 Hardee LK. Quality improvement: Universal protocol use in office-based gastrointestinal procedure units. Gastroenterology Nursing. 2012;35(6):380-382. [pmid: 23207780].
220 Takala RSK, Pauniaho SL, Kotkansalo A, et al. A pilot study of the implementation of WHO Surgical Checklist in Finland: Improvements in activities and communication. Acta Anaesthesiologica Scandinavica. 2011;55(10):1206-1214. [pmid: 22092125].
221 Haynes AB, Weiser TG, Berry WR, et al. A surgical safety checklist to reduce morbidity and mortality in a global population. N Engl J Med. Jan. 29. 2009;360(5):491-499. [pmid: 19144931].
222 Rosenfield LK, Chang DS. Flash fires during facial surgery: recommendations for the safe delivery of oxygen. Plast Reconstr Surg. May. 2007;119(6):1982-1983. [pmid: 17440416].
223 Be aware of fuel sources, ignition to reduce fire risk: how safe are your drapes, and do you really need to use oxygen?. Same Day Surgery. 2005:1-2.
224 Sadaniantz BT, Wood DA. Fuel safety -- not fires. Nursing Spectrum Florida Edition. 2004;14(12):10-11.
225 Patterson P. Hardwiring the right-site process. OR Manager. 2011;27(8):9-11.
226 Vital CJ, Canegallo J, Bertolasio P, Ward A, Fitzgerald J. Joint Commission and Universal Protocol- Adapting Changes to The Marking Process. Journal of PeriAnesthesia Nursing. 2011;26(3):198.
227 Patterson P. RI standardizes safe-site protocol. OR Manager. 2009;25(9):9-10.
228 Smart wristband designed to prevent wrong-site surgery. Orthopedics Today. 2005;25(9):29.
229 Edel EM. Surgical count practice variability and the potential for retained surgical items. AORN J. Feb. 2012;95(2):228-238. [pmid: 22283914].
230 Tripathi A, Marentis TC, Chronis N. Microfabricated Instrument Tag for the Radiographic Detection of Retained Foreign Bodies During Surgery. Medical Imaging 2012: Physics of Medical Imaging. 83132012.
231 Su CJ, Chou TC. Improving patient safety and control in operating room by leveraging RFID technology. Imecs 2008: International Multiconference of Engineers and Computer Scientists, Vols I and Ii. 2008:1719-1724.
232 Torner N. Organizations collaborate to prevent surgical fires. Mater Manag Health Care. Feb. 2007;16(2):42-43. [pmid: 17367053].
233 Albataineh J, Salem Y, Jaffar M. Preventing operating room fire: an alternate approach. Anesth Analg. Oct. 2006;103(4):1051-1052. [pmid: 17000844].
234 Meneghetti SC, Morgan MM, Fritz J, Borkowski RG, Djohan R, Zins JE. Operating room fires: optimizing safety. Plast Reconstr Surg. Nov. 2007;120(6):1701-1708. [pmid: 18040210].
235 Salmon L. Fire in the OR--prevention and preparedness. AORN J. Jul. 2004;80(1):42-48. 51. 44. quiz 57-60. [pmid: 15315272].
236 Patterson P. Preventing retained surgical items: what role does technology play?. OR Manager. Nov. 8. 2009;25(11):1-9. 11.
237 Minnesota's retained object protocol. OR Manager. Dec. 2008;24(12):14. 16.
238 Castelluccio D. Implementing AORN Recommended Practices for Laser Safety. AORN J. May. 2012;95(5):612-624. quiz 625-617. [pmid: 22541772].
239 DeMaria S Jr, Schwartz AD, Narine V, Yang S, Levine AI. Management of intraoperative airway fire. Simulation in healthcare : journal of the Society for Simulation in Healthcare. Dec. 2011;6(6):360-363. [pmid: 21613968].
240 Davies J, Griffith G. Preventing fires due to supplemental oxygen. Anaesthesia. Apr. 2011;66(4):320-321. [pmid: 21401559].
241 Getting the whole team on board to prevent retained foreign bodies. OR Manager. Sep. 15. 2008;24(9):1-18.
242 Panesar SS, Cleary K, Sheikh A. National Patient Safety Agency leads national implementation of measures to reduce the incidence of retained surgical materials. Surgeon. Feb. 2010;8(1):54-55. [pmid: 20222405].
243 Mathias JM. Preventing retained items: time to consider technology?. OR Manager. Jan. 18. 20. 2011;27(1):1-12.
244 Reece M, Troeleman ND, McGowan JE, Furuno JP. Reducing the incidence of retained surgical instrument fragments. AORN J. Sep. 2011;94(3):301-304. [pmid: 21884851].
245 Steelman VM, Alasagheirin MH. Assessment of radiofrequency device sensitivity for the detection of retained surgical sponges in patients with morbid obesity. Arch Surg. Oct. 2012;147(10):955-960. [pmid: 23070411].
246 Sandlin D. SurgiChip--new technology for prevention of wrong site, wrong procedure, wrong person surgery. J Perianesth Nurs. Apr. 2005;20(2):144-146. [pmid: 15806534].
247 Sandberg WS, Hakkinen M, Egan M, et al. Automatic detection and notification of “wrong patient-wrong location” errors in the operating room. Surgical innovation. Sep. 2005;12(3):253-260. [pmid: 16224648].
248 Page L. System marks new method of preventing wrong-site surgery. Mater Manag Health Care. Feb. 2006;15(2):55-56. [pmid: 16583616].
249 Patterson P. Pinpointing risks of wrong surgery. OR Manager. Aug. 2011;27(8):7-8.
250 Rosenfield LK, Chang DS. The error of omission: a simple checklist approach for improving operating room safety. Plast Reconstr Surg. Jan. 2009;123(1):399-402. [pmid: 19116578].
251 National Center for Patient Safety. Ensuring Correct Procedures. Presentation. 2013.
252 Watts BV, van Citters D, Shiner B, Mills PD. Developing unique engineering solutions to improve patient safety. Journal of Healthcare Engineering. 2012;3(3):431-442.
253 France DJ, Leming-Lee S, Jackson T, Feistritzer NR, Higgins MS. An observational analysis of surgical team compliance with perioperative safety practices after crew resource management training. The American Journal of Surgery. 2008;195(4):546-553. [pmid: 18304501].
254 McLaughlin N, Winograd D, Chung HR, Van de Wiele B, Martin NA. University of California, LosAngeles, surgical time-out process: Evolution, challenges, and future perspective. Neurosurgical Focus. 2012;33(5).
255 Fabian CE. Electronic tagging of surgical sponges to prevent their accidental retention. Surgery. Mar. 2005;137(3):298-301. [pmid: 15746781].
256 Pagliarello C, Paradisi A, Dianzani C, Paradisi M, Persichetti P. Avoiding surgical errors by referencing anatomical landmarks. British Journal of Dermatology. 2012;167(4):951-952. [pmid: 22486231].
257 Al-Rawi H, Varma S. The use of a hand-held mirror to reduce litigation and improve communication in dermatological surgery. British Journal of Dermatology. 2012;167(2):446-447. [pmid: 22292972].