# METHODS

## TOPIC DEVELOPMENT

This project was nominated by the VA National Center for Patient Safety. The key questions were developed with input from a technical expert panel consisting of Dr. Douglas Paull, VA National Center for Patient Safety; Robin Hemphill, Director, VA National Center for Patient Safety; Dr. Verna Gibbs, Director, No Thing Left Behind, surgeon/expert in prevention of retained surgical items and surgical fires; Dr. Mark Wilson, Medical Director, VA Surgery Quality Improvement Program, National Surgery Office; and Dr. Edward Dunn, Director of Systems Redesign, surgeon/expert in prevention of wrong site surgery and team training.

The final key questions are:

Key Question 1. What is the prevalence of: wrong site surgery, retained surgical items, and surgical fires?

Key Question 2. What are the identified root causes of: wrong site surgery, retained surgical items, and surgical fires?

Key Question 3. What is the quality of current guidelines in use to prevent wrong site surgery, retained surgical items, and surgical fires?

Key Question 4. What is the effectiveness of the individually identified interventions for the prevention of wrong site surgery, retained surgical items, and surgical fires?

## SEARCH STRATEGY

We searched the databases PubMed, CINAHL, CENTRAL and Web of Science to identify individual studies and reviews. The database SCOPUS which includes patent databases and IEEE XPlore focusing on technology were searched to identify technological advances, in particular supporting the prevention of retained surgical items.

In addition to the electronic database search, we scanned the references of included studies and existing reviews and searched the Cochrane Effective Practice and Organisation of Care (EPOC) Group Specialised Register and PubMed Health. Finally, we consulted subject matter experts for pertinent literature.

The medical literature contains many publications giving advice or guidance about preventing wrong site surgery, retained surgical items, or surgical fires. We used the Institute of Medicine definition to determine what publications are “guidelines”. To identify relevant practice guidelines, our primary search was performed by staff at the National Guidelines Clearinghouse (www.guidelines.gov). The Clearinghouse is an initiative of the Agency for Healthcare Research and Quality, whose mission is “to provide physicians and other health professionals, healthcare providers, health plans, integrated delivery systems, purchasers, and others an accessible mechanism for obtaining objective, detailed information on clinical practice guidelines”. An advantage of using the Clearinghouse is that in order to be listed, a document has to meet a certain set of inclusion criteria, one of which is a standard definition of “clinical practice guideline”. Guidelines do not have to be published in the peer reviewed literature in order to be listed in the Clearinghouse, an advantage over computerized database searches in this regard. We supplemented the National Guideline Clearinghouse search with a Google search of guidelines and the topics of interest. The top 20 search results were reviewed by two physician researchers.

Searches were undertaken in February 2013 to identify studies and guidelines published since 2004. The start search date of 2004 was selected to provide currently relevant prevalence estimates, root cause analyses of incidents despite the widely implemented Universal Protocol, and interventions and guidelines building on the Universal Protocol and the discussion for safety in surgery sparked by its implementation. The guideline search was supplemented by a Google search in September 2013 to capture the most current existing guidelines. Searches were restricted to English-language publications as US, and in particular VA-relevant publications, were sought.

## STUDY SELECTION

Two independent reviewers screened the titles and abstracts as well as publications obtained as full text for inclusion in the review. Discrepancies in the full text inclusion screening process were discussed in the review team.

Key Question 1 (prevalence) Inclusion Criteria
- Participants: Data from patients undergoing surgery were eligible for inclusion in the review.
- Intervention: Data from surgical procedures including incisions were eligible for inclusion in the review. Studies exclusively focusing on injections or minimally invasive procedures were not sought.
- Comparator (study design): Studies focusing on prevalence data (i.e., referring to prevalence in the title or abstract of the publication) were eligible for inclusion in the review. Studies reporting a numerator and denominator (e.g., per procedures or lifetime prevalence per surgeon), or a rate were included. In addition, event estimates reported in included root cause analyses (see Key Question 2) and intervention studies (see Key Question 4) with a minimum sample size of 10,000 for wrong site surgery, 100 for retained surgical items, and 1,000 for surgical fire were extracted. Studies reported in scientific journals were eligible for inclusion, raw data from organizational reports were not sought.
- Outcome: Studies reporting the frequency of wrong site surgery, unintentionally retained surgical item, or surgical fire events are eligible for inclusion in the review. Wrong site surgery was defined as wrong site, wrong side, wrong level, wrong procedure, wrong implant, or wrong patient. Events of retained surgical items refer to unintentionally retained surgical items and were not limited to those with documented adverse events for patients. Publications reporting on intentionally placed but then forgotten items, such as stents, or unintentionally lost or broken equipment which was noticed during the procedure and not retained, were excluded. Surgical fires were defined as fires in the operating room or settings for surgical procedures and were not limited to fires on the patient. Studies reporting only on composite outcomes of never events were excluded.
- Timing: Studies reporting data since the implementation of the Universal Protocol in 2004 were eligible for inclusion in the review; studies exclusively reporting on older prevalence data were excluded.
- Setting: Data from US facilities were eligible for inclusion in the review. Only fires during surgical procedures were included (not all incidents of fires in hospitals or other healthcare facilities).

Key Question 2 (root causes) Inclusion Criteria
- Participants: Information from staff or patients undergoing surgery was eligible for inclusion in the review. We excluded experimental studies investigating, for example, the flammability of surgical material.
- Intervention: Root cause or risk factor analyses related to surgical procedures were eligible for inclusion in the review. Analyses of surgical procedures including incisions were eligible for inclusion in the review. Studies exclusively focusing on injections or minimally invasive procedures were not sought.
- Comparator (study design): Empirical studies with assessments of incidence were eligible for inclusion in the review. Results of an institutional investigation for one case or literature/database review analyzing more than one case were included. We excluded case reports without reference to a formal, institutional root cause analysis.
- Outcome: Identified causes and risk factors of wrong site surgery, retained surgical items, or surgical fires were eligible for inclusion in the review. Wrong site surgery was defined as wrong site, wrong side, wrong level, wrong procedure, wrong implant, or wrong patient. Incidents of retained surgical items refer to unintentionally retained items and were not limited to those with documented adverse events for patients. Publications reporting on intentionally placed but then forgotten items, such as stents, or unintentionally lost or broken equipment which was noticed during the procedure and not retained, were excluded. Surgical fires were defined as fires in the operating room or settings for surgical procedures and were not limited to fires on the patient. Studies had to differentiate root cause or risk factor analyses by event to be included, studies using composite outcomes of never events were excluded.
- Timing: Root cause analyses since the implementation of the Universal Protocol in 2004 were eligible for inclusion in the review; studies exclusively reporting on incidents occurring earlier were excluded. Only fires during surgical procedures were included.
- Setting: Data from international facilities that are applicable to VA settings were eligible for inclusion in the review.

Key Question 3 (quality of guidelines) Inclusion Criteria
- Participants: Guidelines aimed at staff or patients were eligible for inclusion in the review.
- Intervention (content): Guidelines addressing the prevention of wrong site surgery or other invasive procedures, the prevention of retained items in surgery or other invasive procedures, and/or the prevention of surgical fires were eligible for inclusion in the review. Wrong site surgery was defined as wrong site, wrong side, wrong level, wrong procedure, wrong implant, or wrong patient. The prevention of retained items refers to unintended retained items and was not limited to those causing adverse events for patients. Surgical fires refer to fires in the operating room or settings for surgical or other invasive procedures and was not limited to fires on the patient.
- Comparator (study design): Guidelines registered with the National Guideline Clearinghouse (http://guideline.gov/about/inclusion-criteria.aspx) were included. The National Guideline Clearinghouse's criteria for guidelines are: 1. The clinical practice guideline contains systematically developed statements that include recommendations, strategies, or information that assists physicians and/or other healthcare practitioners and patients to make decisions about appropriate healthcare for specific clinical circumstances. 2. The clinical practice guideline was produced under the auspices of medical specialty associations; relevant professional societies, public or private organizations, government agencies at the Federal, State, or local level; or healthcare organizations or plans. A clinical practice guideline developed and issued by an individual not officially sponsored or supported by one of the above types of organizations does not meet the inclusion criteria for NGC. 3. Corroborating documentation can be produced and verified that a systematic literature search and review of existing scientific evidence published in peer reviewed journals was performed during the guideline development. A guideline is not excluded from NGC if corroborating documentation can be produced and verified detailing specific gaps in scientific evidence for some of the guideline's recommendations. 4. The full text guideline is available upon request in print or electronic format (for free or for a fee), in the English language. The guideline is current and the most recent version produced. Documented evidence can be produced or verified that the guideline was developed, reviewed, or revised within the last five years.
- Outcome: Guideline development characteristics and a summary of the underlying evidence base for the guideline were reviewed. Publications without documentation of having been informed by a systematic review were not considered guidelines and were rejected.
- Timing: Guidelines published since 2004 were eligible for inclusion in the review.
- Setting: Guidelines applicable to VA settings were eligible for inclusion in the review.

Key Question 4 (effectiveness of interventions) Inclusion Criteria
- Participants: Interventions targeting staff or patients involved in surgical or other invasive procedures including preoperative staff were eligible for inclusion in the review.
- Intervention: Interventions addressing the prevention of wrong site surgery or other invasive procedures, retained items in surgical or other invasive procedures, and/or fires in the operating room or settings for surgical or other invasive procedures were eligible for inclusion in the review. Local guideline implementations were included. Interventions aiming to prevent the loss of intentionally placed but then forgotten items, such as stents, were excluded. General fire drills not targeted towards surgical fire prevention were excluded. Evaluations of interventions not specifically addressing the prevention of wrong site surgery, retained surgical items, or surgical fires but reporting on incidents or near misses of the events were also included.
- Comparator (study design): Controlled studies (concurrent control group [e.g., RCT], or studies with historic control group (pre-post study), and uncontrolled studies (post-only) were eligible for inclusion in the review.
- Outcome: Studies reporting wrong site surgery, retained surgical item, and surgical fire incidents; wrong site surgery, retained surgical item, or surgical fire near misses (close calls, e.g., wrong procedure started but not completed) were eligible for inclusion in the review. Studies presenting data on safety perceptions with regard to wrong site surgery, retained surgical items, and surgical fires were included; studies only reporting on the feasibility or compliance with interventions were not eligible. Wrong site surgery was defined as wrong site, wrong side, wrong level, wrong procedure, wrong implant, or wrong patient. Incidents of retained items refer to unintentionally retained items in surgery or other invasive procedures and were not limited to those with documented adverse events for patients. Surgical fires refer to fires in the operating room and settings for surgical or other invasive procedures and were not limited to fires on the patient. Secondary outcomes were adverse events associated with the intervention, intervention compliance, and other pertinent intervention-specific outcomes.
- Timing: Evaluations published since 2004 were eligible for inclusion in the review. Interventions may apply to the period before, during, and after surgery. Outcomes may be collected before, during or after surgery.
- Setting: Studies in clinical settings were eligible for inclusion in the review.

## DATA ABSTRACTION

The data extraction was performed by one reviewer and checked by a second reviewer using a pilot tested and standardized data extraction form. Discrepancies were resolved through discussion in the review team.

For Key Question 1 (prevalence), we abstracted the incidence and the denominator, the timeframe, together with details about the setting, pertinent context information such as existing prevention protocols; separately for wrong site surgery, retained surgical items, and surgical fires. We extracted the type of surgery and categorized studies broadly. We differentiated the denominator, surgical events and near misses, or composite outcomes of events and near misses, or composite outcomes of surgical and other invasive procedure events.

For Key Question 2, the identified root causes for each of the events or composite outcomes were documented in an evidence table summarizing details of the investigated incident, the assessment context and format, and the identified root causes and risk factors.

For Key Question 3, we documented the identified current guidelines in use to prevent wrong site surgery, retained surgical items, and surgical fires. We summarized the scope and intended use of the guideline in an evidence table. The quality of the guideline taking the development of the guideline as well as the underlying evidence into account is also documented.

For Key Question 4, we documented the setting and type of surgery, the study design, the number of patients, participants and/or surgical procedures, and the follow up period. We categorized the focus of the intervention and extracted the intervention components, as well as information on the compliance with the intervention. We extracted the effectiveness results of the intervention in terms of wrong site surgery, retained surgical item, and surgical fire incidents and/or near misses separately for each of the targeted events in evidence tables. In addition, we abstracted adverse events associated with the intervention as well as intervention specific outcomes such as provider perceptions of safety and composite outcomes (e.g., a composition of events and near misses or composite outcomes of events of interest).

We differentiated post-only, pre-post, cohort studies comparing two cohorts, controlled trials with intervention assigned by the investigator, and randomized controlled trials (RCTs) with patients randomly assigned to the treatment or control group.

## QUALITY ASSESSMENT

Quality ratings were performed by two independent reviewers. Discrepancies were resolved through discussion in the review team.

The identified prevalence studies (Key Question 1) are very heterogeneous with diverse samples and assessment methods. We differentiated studies based on the chosen denominator for prevalence estimates such as per procedure or lifetime prevalence per surgeon and highlighted methodological issues limiting the validity of the studies in the narrative synthesis.

The identified root cause analyses (Key Question 2) were very heterogeneous with unique analytic designs. We ranked included analyses based on the number of investigated incidents.

The guidelines (Key Question 3) were assessed using the Appraisal of Guidelines for Research & Evaluation (AGREE II) instrument to assess the 4 guidelines (ref AGREE II, www.agreetrust.org). AGREE was developed to address issues of variability in guideline quality – as the usefulness of a guideline and its recommendations are only as good its own quality. The tool quantitatively assesses the methodological rigor and transparency of how the guideline was developed and presented. The quality of the guideline is defined as the “confidence that the potential biases of development have been addressed and that recommendations are both internally and externally valid and feasible.” The AGREE instrument assesses 23 criteria in 6 domains (ranging from 3-10 criteria per specific domain): scope and purpose (3 criteria), stakeholder involvement (3), rigor of development (10 criteria), clarity of presentation (3 criteria), applicability (4 criteria) and editorial independence (2). Each criterion is rated on a scale of 1-10. Details of the criteria are provided in the evidence table.

The identified interventions studies (Key Question 4) were very heterogeneous with regard to settings, reported data, employed study designs, followup periods, and reported details on the intervention. The evidence tables highlight VA-settings and differentiate US and non-US studies. Study design-specific critical appraisal was not performed as the majority of studies used very limited study design such as post-only studies without any comparator or pre-post studies using only a historical comparator. The study design, the outcome characteristics, and the followup period were incorporated into the synthesis.

## DATA SYNTHESIS

The information was tabulated in evidence tables to allow a comprehensive overview of the existing evidence. Results were summarized in a narrative synthesis documenting the range of results. Identified intervention studies were very diverse therefore results were not statistically pooled but summarized in a narrative review. We performed subgroup analyses for evidence from VA settings where possible.

Prevalence, root cause analysis, and intervention studies were grouped by event (wrong site surgery, retained surgical items, surgical fires). Prevalence estimates were transposed to event per 10,000 performed surgical procedures to allow comparisons across studies and differentiated general surgery estimates and surgical specialty data. Root cause analyses were ordered by the number of analyzed events.

Interventions for wrong site surgery were grouped as global Universal Protocol mandate evaluations; preoperative verification, site marking, time out, briefing and checklist implementations; team training and education, and equipment-related interventions. Interventions for retained surgical items were grouped as counting and imaging protocols, team training, and equipment-related interventions. Interventions to prevent surgical fires were grouped as education, equipment-related, or other approaches.

## RATING THE BODY OF EVIDENCE

Strength of evidence ratings for intervention studies were drafted by one reviewer and finalized in the review team. We assessed the overall quality of evidence for outcomes using a method developed by the GRADE Working Group. We took the number of studies per intervention, the study designs and inherent limitations, the consistency of results across studies, whether direct or indirect evidence was available, the precision of the results, and publication bias into account.

The GRADE Working Group classifies the grade of evidence across outcomes according to the following criteria:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

## PEER REVIEW

A draft version of this report was reviewed by technical experts as well as clinical leadership. Their comments and our responses are presented in Appendix B.

The PROSPERO registration number is CRD42013004524.