# INTRODUCTION

## STATEMENT OF THE PROBLEM

This systematic review provides an overview over the prevalence, the root causes, existing guidelines, and the effectiveness of interventions to prevent wrong site surgery, retained surgical items, and surgical fires.

Wrong site surgery refers to surgery on the wrong site, the wrong side, the wrong procedure, the wrong implant, or the wrong patient. This encompasses all incidents ranging from wrong-level operations in spine surgery due to complicated diagnostics as well as dramatic cases such as wrong limb amputation. The distinction between wrong site surgery and near-miss is blurred where incisions on the wrong site, e.g., burr holes are concerned. Retained surgical items are items unintentionally left behind in the patient after surgery. The most common type of retained item is a surgical sponge; the mass lesion due to the sponge surrounded by foreign-body reaction is referred to as gossypiboma, textiloma, gauzoma, or muslinoma depending on the material.1 Some incidents are discovered many years after the surgery, not all incidents are clinically symptomatic, and the event describes unintentionally retaining the entire item as well as device fragments. Surgical fires describe fire incidents in the operating room, including fires on the patients and in the patient, for example airway fires during tracheostomy.

All three events have been targeted by patient safety agencies and professional organizations and many states have mandatory reporting requirements. The events can potentially have devastating consequences for the patients as well as healthcare providers and facilities. Legally, “res ipsa loquitur” (the thing itself speaks) is most likely to apply due to the nature of the events, e.g., wrong site surgery is wrong regardless of the circumstances, and a successful legal defense will be very difficult.2-5 Most importantly, all three events are considered preventable and must not be deemed to be an acceptable risk of surgery. The events have been termed “Never Events,” i.e., events that should never happen.

The National Quality Forum has determined wrong site surgery and retained surgical items to be Serious Reportable Events (defined as events that are errors in medical care that are clearly identifiable, preventable, and serious in their consequences for patients, and that indicate a real problem in the safety and credibility of a healthcare facility) in 2002 and in the current list (defined as unambiguous, largely preventable, and serious as well as adverse, indicative of a problem in a healthcare setting's safety systems, or important for public credibility or accountability); fires in the operating room are included in the Environmental Events.6 The Joint Commission has issued sentinel event alerts for wrong site surgery as well as surgical fires.7,8 A sentinel event is an unexpected occurrence involving death or serious physical or psychological injury, or the risk thereof and serious injury specifically includes loss of limb or function.9

### Prevalence

It is safe to assume that the events wrong site surgery, retained surgical items, and surgical fires are rare events; however, specific estimates of the prevalence of their occurrence in clinical practice are sparse. Although preventable and despite a number of national and international efforts, by professional organizations and state agencies; information, training and available resources10; incidents of wrong site surgery, retained surgical items, and fires in the operating room continue to exist.

### Root Causes

The last decade has emphasized surgical safety and several preventative measures have been publicized. The Universal Protocol, the result of a concerted effort to improve surgical safety after a thorough review of root causes, has been implemented in 2004 for Joint Commission accredited hospitals. Risk factors for retained surgical items have received mainstream attention in 2003 after the publication of a landmark study.11 The Joint Commission issued a sentinel event alert regarding the prevention of surgical fires in 2003.^8^ This review concentrates on root causes of occurrences reported since 2004, i.e., in the post-Universal Protocol era that has seen a strong focus on surgical safety. A root cause analysis is a tool for identifying the underlying causes of surgical patient safety problems.12 Performing a root cause analysis after sentinel events is mandatory for Joint Commission accredited hospitals.

For wrong site surgery incidents in particular it is generally assumed that multiple processes, rather than one specific error, will have contributed to an event.13 Root cause analyses for retained surgical items are complicated by the delay with which they are discovered making it in many cases impossible to reconstruct the causal chain. Surgical fires are rare, however, the presence of fuels, oxidizers, as well as ignition sources are commonly present in surgical settings. Historically, the use of flammable inhalation anesthetics was associated with surgical fires,14,15 however, many patients receive oxygen during surgery and operating theatres need to be considered an oxygen-enriched environment where fires will develop more quickly, burn hotter, and are more difficult to extinguish.16

### Guidelines

A substantial number of recommendations for clinical practice have been published. All three events are rare, but are known surgical safety problems. The Joint commission Universal Protocol has been in effect for accredited hospitals since July 2004 and is endorsed by numerous professional associations and organizations.17 The VA established a directive on Ensuring Correct Surgery and Invasive Procedures in January 2003 and updated it in 2004 to conform with the Universal Protocol and to extend it to healthcare settings outside the operating room.18 The first case of retained sponges in the medical literature was reported by Wilson in 1884^19^ and more than one separate sponge and instrument count, e.g., preoperative, intraoperative, and before closure of the incision, and the use of radiopaque sponges has been suggested a decade ago.20 Flammable and explosive anesthetic gases have been avoided for decades and the inherent dangers of electrosurgical units surgical lasers are known.15,21-24 The National Guideline Clearinghouse is a public repository of evidence-based guidelines.

### Effectiveness of Interventions

The Universal Protocol has three components: 1) preoperative verification of the patient, 2) marking of the surgical site when applicable, and 3) performing a “time-out” before the procedure begins. The success of the protocol depends on the adherence to the components. Retained surgical items has been traditionally addressed by surgical counting protocols, however, advances in technology have also made accounting procedures known in commercial fields such as bar coding available to surgery.25,26 Technical equipment can be the cause of the fires; however, it is also possible to target the team interaction in the operating room in order to prevent fires and to reduce fire damage. Surgeons are most often in control of the ignition sources such as lasers, anesthesia providers typically control the flow of oxygen, and circulating nurses control the fuels such as drapes.27,28

This report aims to summarize the available evidence on interventions aiming to prevent wrong site surgery, retained surgical items, and surgical fires. To this end we aimed to identify evaluations of interventions to determine their effectiveness. The research area is impeded by two restrictions. The evaluated interventions are often organizational in nature and the events of interest are rare events. Given the known paucity of study designs traditionally used in evidence-based medicine such as randomized controlled trials (RCTs) in patient safety research, we have included research studies that are typically outside the scope of evidence reviews such as pre-post and post only analyses. Research on rare events is very difficult to conduct. Large samples or long periods of time are necessary to determine whether a patient safety practice has reduced the incidence of an already rare effect. The most prominent surgical safety guideline, the Universal Protocol, is not based on traditional research evidence from intervention evaluations. For this review we aimed to summarize the existing empirical research, meaning evaluations of interventions that report on the outcomes of interest, i.e., wrong site surgery, retained surgical items, and surgical fires. The desired incidence of the event is zero and post-only studies may show us whether the desired goal was achieved with the implemented intervention.

## OBJECTIVES OF THE REVIEW

The VA National Center for Patient Safety has requested an evidence review to examine the prevalence of and the root causes of wrong site surgery, retained surgical items, and surgical fires. The evidence review also evaluates current guidelines and the effectiveness of interventions for the prevention of these events. Studies examining VA-specific data are of special interest. The evidence synthesis will be used to develop a standardized, single, strong recommendation to VA cacilities in the effort to eliminate these events.