# SEARCH STRATEGIES

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1/1/2004-2/2013

LANGUAGE: English

SEARCH #1:

surgery OR surgical OR operating room* OR surgical procedures, operative OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

wrong-site OR wrong-patient* OR wrong*[ti] OR incorrect[ti] OR mistake*[ti] OR never-event* OR “never event” OR “never events” OR Universal Protocol

NOT

animal* NOT (human OR humans)

SEARCH #2:

(surgery OR surgical OR operating room* OR surgical procedures, operative OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

(retain*[ti] OR unretriev*[ti] OR forgot*[ti] OR forget*[ti]

AND

item OR items OR foreign body OR foreign bodies OR fragment* OR instrument* OR tool OR tools OR device* OR sponge* OR screw* OR needle* OR swab* OR knife blade* OR pin OR pins OR scalpel* OR clamp* OR scissors OR towel* OR electrosurgical adapter* OR tweezer* OR forceps OR tip OR tips OR tube OR tubes OR tubing OR scope OR scopes OR ultrasound tissue disruptor* OR bulb OR bulbs OR laser guide* OR guide wire* OR guidewire* OR guide-wire*)

OR “device loss” OR device-loss)

OR

gossypiboma* OR textiloma* OR muslinoma* OR gauzoma* OR “muslin-induced” OR “muslin induced”

NOT

animal* NOT (human OR humans)

SEARCH #3:

surgery OR surgical OR operating room* OR surgical procedures, operative OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

fire OR fires

NOT

animal* NOT (human OR humans)

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science – 1/2004-2/2013

LANGUAGE: English

SEARCH STRATEGY:

Topic=(surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative)

AND

Topic=(wrong-site OR wrong-patient* OR never-event* OR “never event” OR “never events”) OR Title=(wrong OR mistake* OR incorrect*) OR (Title=(retain* OR unretriev* OR forgot* OR forget*) AND Topic=(item OR items OR foreign body OR foreign bodies OR fragment* OR instrument* OR tool OR tools OR device* OR sponge* OR screw* OR needle* OR swab* OR knife blade* OR pin OR pins OR scalpel* OR clamp* OR scissors OR towel* OR electrosurgical adapter* OR tweezer* OR forceps OR tip OR tips OR tube OR tubes OR tubing OR scope OR scopes OR ultrasound tissue disruptor* OR bulb OR bulbs OR laser guide* OR guide wire* OR guidewire* OR guide-wire*)) OR Topic=(fire OR fires) OR Topic=(“Universal Protocol”)

OR Topic=(gossypiboma*) OR Topic=(textiloma OR muslinoma* OR gauzoma* OR “muslin-induced” OR “muslin induced”)

DATABASE SEARCHED & TIME PERIOD COVERED:

CINAHL – 1/2004-2/2013

LANGUAGE: English

SEARCH STRATEGY:

surgery OR surgical OR operating room* OR surgical procedures, operative OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

wrong-site OR wrong-patient* OR never-event* OR “never event” OR “never events” OR “Universal Protocol” OR TI ( wrong* OR incorrect OR mistake* ) OR (TI ( retain* OR unretriev* OR forgot* OR forget* ) AND ( item OR items OR foreign body OR foreign bodies OR fragment* OR instrument* OR tool OR tools OR device* OR sponge* OR screw* OR needle* OR swab* OR knife blade* OR pin OR pins OR scalpel* OR clamp* OR scissors OR towel* OR electrosurgical adapter* OR tweezer* OR forceps OR tip OR tips OR tube OR tubes OR tubing OR scope OR scopes OR ultrasound tissue disruptor* OR bulb OR bulbs OR laser guide* OR OR guide wire* OR guidewire* OR guide-wire*)) OR fire OR fires OR gossypiboma* OR textiloma OR muslinoma* OR gauzoma* OR “muslin-induced” OR “muslin induced”

NUMBER AFTER REMOVAL OF DUPLICATES (PubMed, CINAHL, Web of Science): 3379

DATABASE SEARCHED & TIME PERIOD COVERED:

SCOPUS – 1/2004-2/2013

LANGUAGE: English

SEARCH STRATEGY: #1

surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

wrong-site OR wrong-patient* OR never-event* OR “never event” OR “never events” OR “Universal Protocol”

SEARCH STRATEGY: #2

surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

TITLE(wrong* OR mistake* OR incorrect)

SEARCH STRATEGY: #3

surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

TITLE(retain* OR unretriev* OR forgot* OR forget*)

SEARCH STRATEGY: #4

surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

fire OR fires

SEARCH STRATEGY: #5

Gossypiboma* OR textiloma OR muslinoma* OR gauzoma* OR “muslin-induced” OR “muslin induced”

SEARCH STRATEGY: #6

TITLE-ABS-KEY(surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative)

AND

TITLE-ABS-KEY(retain* OR unretriev* OR forgot* OR forget*)

AND

TITLE-ABS-KEY(item OR items) OR (TITLE-ABS-KEY(foreign body OR foreign bodies OR fragment* OR instrument* OR tool OR tools OR device* OR sponge* OR screw* OR needle* OR swab* OR knife blade*) OR (TITLE-ABS-KEY(pin OR pins OR scalpel* OR clamp* OR scissors OR towel* OR electrosurgical adapter*) OR (TITLE-ABS-KEY(tweezer* OR forceps OR tip OR tips OR tube OR tubes OR tubing OR scope OR scopes OR ultrasound tissue disruptor* OR bulb OR bulbs OR laser guide* OR guide wire* OR guidewire* OR guide-wire*)

OR

TITLE-ABS-KEY(surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative)

AND

(TITLE-ABS-KEY(“device loss” OR device-loss)

TOTAL AFTER REMOVAL OF DUPLICATES AND DELETION OF “Animal NOT Human” FROM KEYWORDS: 1317

DATABASE SEARCHED & TIME PERIOD COVERED:

IEEE XPlore – 1/2004-2/2013

LANGUAGE: English

SEARCH STRATEGY #1:

surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

wrong-site OR wrong-patient* OR never-event* OR “never event” OR “never events” OR “Universal Protocol”

SEARCH STRATEGY #2:

surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

wrong OR mistake* OR incorrect

SEARCH STRATEGY #3:

surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

retain OR retains OR retaining OR unretriev* OR forgot OR forgotten OR forget OR forgets OR forgetting

SEARCH STRATEGY #4:

surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

fire OR fires

SEARCH STRATEGY #5:

surgery OR surgical OR operating room* OR perioperative OR peri-operative OR preoperative OR pre-operative

AND

(“device loss” OR device-loss

SEARCH STRATEGY #6:

gossypiboma* OR textiloma OR muslinoma* OR gauzoma* OR “muslin-induced” OR “muslin induced”

NUMBER OF RESULTS: 99

DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane CENTRAL - 1/2004-2/2013

LANGUAGE: English

SEARCH STRATEGY:

surgery or surgical or operating room* or surgical procedures, operative or perioperative or peri-operative or preoperative or pre-operative:ti,ab,kw

AND

wrong-site or wrong-patient* or wrong* or incorrect or mistake* or never-event* or “never event” or “never events” or Universal Protocol:ti,ab,kw OR “device loss” or device-loss OR gossypiboma* or textiloma* or muslinoma* or gauzoma* or “muslin-induced” or “muslin induced” OR fire or fires

OR

surgery or surgical or operating room* or surgical procedures, operative or perioperative or peri-operative or preoperative or pre-operative:ti,ab,kw

AND

retain* or unretriev* or forgot* or forget*

AND

item or items or foreign body or foreign bodies or fragment* or instrument* or tool or tools or device* or sponge* or screw* or needle* or swab* or knife blade* or pin or pins or scalpel* or clamp* or scissors or towel* or electrosurgical adapter* or tweezer* or forceps or tip or tips or tube or tubes or tubing or scope or scopes or ultrasound tissue disruptor* or bulb or bulbs or laser guide* or guide wire* or guidewire* or guide-wire*

NUMBER OF RESULTS AFTER REMOVAL OF DUPLICATES: 91

NUMBER OF DEDUPLICATED RESULTS ALL ELECTRONIC DATABASES: 4868