# METHODS

## TOPIC DEVELOPMENT

This project was nominated by Rajiv Jain, MD (Chief Consultant, Office of Patient Care Services) and Jeffrey Robbins, DPM (Director, Podiatry Service). Our key questions were developed with input from a technical expert panel. We also received guidance from Carolyn Robinson, NP, MSN, and Eric Affeldt, DPM, both from the Minneapolis VA Health Care System.

We address the following key questions:

1. What are the efficacy and harms of therapies for diabetic ulcers? Is efficacy dependent on ancillary therapies? Does efficacy differ according to patient demographics, comorbid conditions, treatment compliance, or activity level?
2. What are the efficacy and harms of therapies for venous ulcers? Is efficacy dependent on ancillary therapies? Does efficacy differ according to patient demographics, comorbid conditions, treatment compliance, or activity level?
3. What are the efficacy and harms of therapies for arterial ulcers? Is efficacy dependent on ancillary therapies? Does efficacy differ according to patient demographics, comorbid conditions, treatment compliance, or activity level?

## SEARCH STRATEGY

We searched MEDLINE (Ovid) for randomized controlled trials (RCTs) published from 1995 to August 2012 using standard search terms. We limited the search to articles with adults and published in the English language. Search terms included: skin ulcer, foot ulcer, leg ulcer, varicose ulcer, diabetic ulcer, diabetic foot, wound healing, venous insufficiency, artificial skin, biological dressings, negative-pressure wound therapy, collagen, silver, topical oxygen, hyperbaric oxygen, electromagnetic, platelet-derived growth factor, platelet-rich plasma, and intermittent pneumatic compression devices. The search strategy is presented in Appendix B.

We did a similar search of the Cochrane Library, and obtained additional articles by a hand-search of reference lists of pertinent studies and systematic reviews and suggestions from members of our technical expert panel.

## STUDY SELECTION

Titles and abstracts were reviewed by researchers trained in the critical analysis of literature. Full text versions of potentially eligible articles were retrieved for review. Our inclusion criteria were as follows:

- Randomized controlled trials
- Studies reported in the English language
- Studies involving adults (18 years and older)
- Intervention must involve collagen-based products, biologic dressings, biologic skin equivalents, keratinocytes, platelet-derived growth factors, platelet-rich plasma, silver products, intermittent pneumatic compression therapy, negative pressure wound therapy, electromagnetic therapy, or hyperbaric or topical oxygen
- Study reports patient outcomes of interest (healed ulcers or time to healing)
- Study published in a peer-reviewed publication after 1995

## DATA ABSTRACTION

We abstracted the following data for each included study: author, date of publication, country where study was conducted, funding source, Therapy type, sample characteristics (gender, age, race/ethnicity, body mass index [BMI], hemoglobin A_1_c [HbA_1_c], smoking status, work days missed, ankle-brachial index [ABI]), ulcer characteristics (type, size, location, grade, duration, infection status), comorbid conditions (hypertension, peripheral vascular disease [PVD], cardiovascular disease, diabetes, or amputation), study inclusion and exclusion criteria, treatment groups, intervention characteristics (product descriptions and application frequency/duration), treatment duration, follow-up duration, study withdrawals, treatment compliance and study quality (allocation concealment, blinding, analysis approach, description of withdrawals). We abstracted primary outcomes (ulcers healed, time to complete ulcer closure, patient global assessment, and return to daily activities) and secondary outcomes (ulcer infection, amputation, revascularization surgery, ulcer recurrence, time to ulcer recurrence, pain or discomfort, hospitalizations, need for home care, quality of life, all-cause mortality, study withdrawals due to adverse events, and allergic reactions to treatment), by ulcer type, for each treatment. We assessed outcomes following treatment and at follow-up, or as reported. All abstraction was done by trained research personnel and verified by a second research associate under the supervision of a Principal Investigator.

## QUALITY ASSESSMENT

We assessed the quality of studies pertaining to the key questions. Individual randomized studies were rated as good, fair, or poor quality based the following criteria: allocation concealment, blinding, analysis approach, and description of withdrawals – a modification of the Cochrane approach to determining risk of bias.13 We assessed studies for applicability to U.S. Veterans.

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies, organized by key question and intervention. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each key question or clinical topic, and drew conclusions based on qualitative synthesis of the findings. Where feasible, results were pooled.

## RATING THE BODY OF EVIDENCE

We assessed the overall strength of evidence using the method reported by Owens et al.14 The overall evidence was rated as: (1) high, meaning high confidence that the evidence reflects the true effect; (2) moderate, indicating moderate confidence that further research may change our confidence in the estimate of effect and may change the estimate; (3) low, meaning there is low confidence that the evidence reflects the true effect; or (4) insufficient, indicating that evidence either is unavailable or does not permit a conclusion.

## PEER REVIEW

A draft version of this report was reviewed by clinical content experts as well as clinical leadership. Their comments and our responses are presented in Appendix C.