# SUMMARY AND DISCUSSION

Chronic lower extremity ulcers are a common and serious health problem. A wide range of standard treatment approaches to achieve ulcer healing are used (e.g., off-loading, compression, leg elevation etc.) based on patient and ulcer factors and provider preferences. While many ulcers heal completely within several weeks, a significant portion either do not heal or increase in size, depth, and severity. These chronic ulcers can result in considerable clinical morbidity and health care costs.

Many types of advanced wound care therapies exist but all represent considerably greater product costs compared to standard therapy. These costs may be justified if they result in improved ulcer healing, reduced morbidity, fewer lower extremity amputations, and improved patient functional status. In addition to the treatment selected, many potential factors contribute to the success or failure of the ulcer healing process including ulcer etiology; ulcer area, depth, duration, and location; patient comorbid conditions; and patient compliance with the treatment protocol. Much of the existing research on advanced wound care therapies has attempted to minimize the influence of many of these factors by limiting enrollment to patients with ulcers of a particular size, including only patients with adequate circulation, and excluding patients taking certain classes of medications.83,84 Furthermore, many of the trials are industry sponsored (55% of the studies included in our review) and the role of the sponsor is typically not stated, definitions of “chronic” ulcers vary widely, and few studies are of sufficient duration to assess whether healing is maintained.84,85

Our systematic review of randomized controlled trials found discouragingly low strength evidence regarding the effectiveness and comparative effectiveness of advanced wound care therapies for treatment of lower extremity ulcers. This was primarily due to the fact that for each ulcer type (diabetic, venous, or arterial) individual categories of advanced wound care therapies were only evaluated in a few studies, often in highly selected populations, and frequently had conflicting findings. Furthermore, within each category of wound care therapies several different types of interventions were used making it difficult to determine if results were replicable in other studies or generalizable to broader clinical settings. Additionally, most studies compared advanced wound care therapies to standard care or placebo. Therefore there is little comparative effectiveness research evaluating one advanced wound care therapy to another. It has been noted that standard care is an inappropriate comparator for studies of advanced therapy since patients have likely already failed standard care.86,87 For arterial ulcers we identified only a single study of any advanced wound care therapy (and this was compared to standard care) despite the clinical importance of arterial ulcers.

However, based on the available findings we conclude that for patients with diabetic chronic ulcers, there is moderate strength of evidence that the biological skin equivalent Apligraf and negative pressure wound therapy improve healing compared to standard care. There is low strength evidence that advanced wound care therapies improved the percentage of ulcers healed compared to standard care for the following therapies: collagen (notably Graftjacket), the biological skin equivalent Dermagraft, platelet-derived growth factors, silver cream, and hyperbaric oxygen therapy but results were not uniform for any treatment group. Most beneficial effects were derived from single or few studies so we recommend caution regarding translating these findings of effectiveness into broader clinical application. Pooled analyses were possible for several therapies and demonstrated a significant improvement in ulcer healing compared to standard care for Apligraf (a biological skin equivalent), platelet-derived growth factors, and negative pressure wound therapy; no improvement was observed for Dermagraft (a biological skin equivalent). Few studies compared one advanced treatment to another but in those studies, no differences in percentage of ulcers healed were found between the two treatment arms. For time to ulcer healing, the pattern of findings was similar and strength of evidence was low for all treatment comparisons reporting that outcome. No studies reported a significant difference in adverse events for any treatment comparison.

Findings for venous ulcers were similar. Although some individual trials of biological dressings (notably OASIS), biological skin equivalents (Apligraf), keratinocytes, silver cream and dressing, and electromagnetic therapy noted significant benefit of the therapy in percentage of ulcers healed compared to standard care, overall the results for each therapy were mixed. In pooled analyses only keratinocytes resulted in significantly better healing compared to standard care. Strength of evidence was moderate for the benefit of keratinocyte therapy and low for the other therapies. Few studies of venous ulcers compared two advanced therapies and, where reported, typically found no differences. Time to ulcer healing was reported infrequently. No advanced wound care therapy was observed to result in an increase in adverse events.

We identified only one study of patients with arterial ulcers despite the clinical importance of this population. It is possible that patients with arterial disease were included in the studies of diabetic ulcers or venous ulcers (i.e., mixed etiology). In one study of patients with non-healing lower extremity ulcers or amputation wounds following a revascularization procedure, Apligraf increased ulcer healing and decreased time to healing compared to standard care with no difference in adverse events.

For amputation wounds, one study of negative pressure wound therapy versus standard care found significantly better healing with no difference in adverse events.

Despite finding benefits of some therapies compared to standard care, the methodological quality of individual studies reviewed was predominantly fair or poor. Common factors limiting the quality were inadequate allocation concealment, no blinding (including no blinding of outcome assessment), failure to use intention-to-treat analysis methods, and failure to adequately describe study dropouts and withdrawals. With methodological flaws, few trials reporting, and heterogeneity in the comparators, study duration, and how outcomes were assessed, the overall strength of evidence was low. While a wide range of patients were enrolled in studies most were older than age 60 years, male, of white race, likely compliant with treatment protocols, and possessed ulcers that were relatively small as measured by surface area. However, authors rarely reported outcomes by patient demographic, comorbidity or ulcer characteristics. Therefore, we found insufficient evidence to guide clinicians and policy makers regarding whether efficacy differs according to patient demographics, comorbid conditions, treatment compliance, or activity level.

## APPLICABILITY AND COST EFFECTIVENESS

It is not well known how outcomes reported in studies of selected populations will translate to daily practice settings including in Veterans Health Administration facilities. There is evidence of good success in ulcer healing with strict adherence to off-loading for diabetic ulcers and compression therapy for venous ulcers.88-91 The patients enrolled in trials were likely more compliant than typical patients and received very close monitoring. Therefore, results from these studies may overestimate benefits and underestimate harms in non-study populations.

Our review was limited to studies of FDA approved products. We excluded studies with wounds of multiple etiologies (e.g., vascular, pressure, trauma, surgery) if they did not report results by etiology. We also excluded studies if they did not report our primary outcomes of healed wounds or time to complete healing. Many studies report change in ulcer size but the clinical benefit of change in ulcer size has not been established.92

Furthermore, we did not conduct cost effectiveness analyses or assess additional costs of care associated with chronic ulcers. Despite the high costs of advanced wound care therapies it is possible that they may be cost effective or even cost saving if found to improve ulcer healing; reduce ulcer associated morbidity, hospitalizations, medical care and amputations; and improve functional status and quality of life. Based on our findings from randomized controlled trials the decision of if, when, and in whom to use advanced wound care therapies as well as the type of advanced wound care therapy selected is difficult. Additionally, because little comparative effectiveness research exists to guide choices, decisions may be based on other factors including wound care product cost, ease of use, and patient and provider preferences (the latter also influenced by personal experience with ulcer and patient characteristics).

## RECOMMENDATIONS FOR FUTURE RESEARCH

Our review highlights several much needed areas for future research. Most studies compared an advanced therapy to either standard ulcer care or placebo treatment. Few studies (10 of the 35 eligible studies of diabetic ulcers, 4 of the 20 eligible studies of venous ulcers, and none for arterial or mixed ulcers) directly compared two advanced therapies. Furthermore, few studies provided a run-in period with carefully monitored standard care to exclude patients for whom carefully monitored standard care would obviate the need for advanced therapy. Therefore, additional randomized trials of advanced wound care therapies versus standard care are needed to replicate or refute current findings. Comparative effectiveness research is also needed to evaluate the relative benefits and harms of different advanced wound care therapies. In both effectiveness and comparative effectiveness research, the sample sizes should be adequate to report specific outcome reporting according to key patient and ulcer characteristics including age, race, gender, and ulcer size, location, and depth. We note below the limitations of the existing research by type of ulcer and therapy assessed.

Of the studies of diabetic ulcers included in this review, only two focused on biological dressings (using different products) and two on platelet-rich plasma. We identified no studies of topical oxygen or electromagnetic therapy. No studies reported on return to daily activities or the need for home care related to ulcer treatment and only one study reported quality of life or hospitalization. The need for amputation or revascularization and the incidence of and time to ulcer recurrence require further investigation. The majority of studies described the ulcers as diabetic foot ulcers with only six providing greater detail about ulcer location. Future research should report healing by ulcer location. Future research should also examine microvascular disease to more clearly distinguish diabetic ulcers from arterial ulcers.

For venous ulcers, we identified only one study of the following advanced wound care therapies: collagen, biological dressings, platelet rich plasma, intermittent pneumatic compression, and hyperbaric oxygen therapy. There were no studies of platelet-derived growth factors or typical oxygen. We found no studies that reported on amputations, time to ulcer recurrence, or need for home health care related to the ulcer. One study reported hospitalization, one study reported quality of life, and two studies reported return to work or daily activities.

We identified only one study of patients with arterial disease requiring advanced wound care following revascularization. Only this study and one other included patients with partial foot amputations with delayed healing. Neither of these studies reported on return to daily activities, pain, quality of life, or need for home health assistance related to the wound. There is a paucity of research on advanced wound care therapies in patients with strictly arterial disease.

In addition to specific topics needing further research, several organizations have outlined overall methodological standards for future research of wound healing therapies (see Appendix E). The standards focus on study design, patient population, comparators, outcomes and outcome assessment, and potential sources of bias. Randomized trials, with allocation concealment and, at a minimum, blinding of third-party outcomes assessors, are recommended. The patient population should be appropriate for the treatment being studied and exclusion criteria should be minimal to enhance generalizability. Endpoints should be selected based on the purpose of the intervention (i.e., closure versus preparation for surgery) and adequate follow-up should be included to confirm healing. Dropouts and study withdrawals should be documented, including withdrawals due to ulcer deterioration. Additional research, conducted in accordance with the standards, is needed to establish the safety and efficacy of advanced wound care therapies. Finally, future research is needed to determine the effectiveness, comparative effectiveness and harms of advanced wound care therapies as used in general clinical practice settings (e.g., vascular and dermatology clinics) where patients may have more severe and larger ulcers, greater comorbidities, or increased difficulty with treatment compliance.