# COMMON METHODOLOGICAL ERRORS AND RECOMMENDATIONS FOR FUTURE CLINICAL TRIALS OF WOUND HEALING

## 1 Common Methodological Errors in Studies of Wound Care

Source:

European Wound Management Association

Gottrup F, Apelqvist J, Price P. Outcomes in controlled and comparative studies on non-healing wounds: recommendations to improve the quality of evidence in wound management. J Wound Care. 2010;19:239-68.

- Lack of validation of subjective assessments
- Lack of description of objective or subjective measures
- Lack of comparable baselines for patient groups
- Lack of blinding for the evaluation of primary outcomes
- Incorrect randomization methods
- Poor definition of primary and secondary objectives
- Number of patients not based on a priori sample size calculation
- Randomization method poorly/not described
- Time to wound healing not a primary objective
- Intention-to-treat analysis not used
- Heterogeneous study population
- Number of and reason for dropouts not stated
- No specification of adjuvant treatments
- Small sample size combined with multiple outcome measures
- Reporting of multiple outcomes over multiple time points (increased chance of type 1 error)
- Poor overall study reporting

## 2 Recommendations for Clinical Trials of Wound Healing

Sources:

Center for Medical Technology Policy

Center for Medical Technology Policy. Effectiveness Guidance Document: Methodological Recommendations for Comparative Effectiveness Research on the Treatment of Chronic Wounds. Version 2.0, October 1, 2012. Available at: http://www.cmtpnet.org/effectiveness-guidance-documents/negative-pressure-wound-therapy-egd/. Accessed October 2012.

European Wound Management Association

Gottrup F, Apelqvist J, Price P. Outcomes in controlled and comparative studies on non-healing wounds: recommendations to improve the quality of evidence in wound management. J Wound Care. 2010;19:239-68.

Panel on Wound Care Evidence-Based Research

Serena T, Bates-Jensen B, Carter MJ, et al. Consensus principles for wound care research obtained using a Delphi process. Wound Repair Regen. 2012;20:284-93. [pmid: 22564224].

US Food and Drug Administration

FDA. Guidance for Industry: Chronic Cutaneous Ulcer and Burn Wounds-Developing Products for Treatment. 2006. Available at: http://www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/UCM071324.pdf. Accessed September 2012

1. “Chronic” needs to be defined or replaced with “non-healing.”
2. Studies should be multi-center to include a range of settings.
3. Studies should focus on one wound type with stratification by risk factors for not healing.
4. Exclusion criteria should be minimal to increase generalizability; rationale for inclusion and exclusion criteria should match the goals of the study.
5. Randomization is critical; baseline wound characteristics have a major effect on outcomes. Non-randomized trials should be considered only when there are barriers to conducting randomized trials that can be identified and explained.
6. Interventions should be clearly described and consistent across all patients.
7. Simultaneous and/or sequential interventions should be evaluated when appropriate.
8. Standard care should be clearly defined and consistent across study sites or balanced using stratification of study sites for multi-site studies; large cohort studies with each wound type should establish outcomes achieved with standard care.
9. Protocols for pain management and treatment of comorbid conditions should be standardized in all study arms.
10. Comparator arms in studies of dressings, medications, etc. should be a “vehicle control arm” with the same components except for the active agent; if the effect of the “vehicle” is not known, there should also be a standard care group only.
11. Blinding of subjects and investigators should be employed if feasible; blinded assessment by a third-party evaluator should be considered if blinding of investigators and patients isn't possible.
12. Outcome assessment tools should be pre-specified and protocols standardized across patients and across study sites for multi-site studies.
13. The patient population should be appropriate for the treatment and type of wound to be studied.
14. A substantial proportion of patients should be drawn from clinical settings where wound care is delivered.
15. Chronic ulcers might heal because patients become more compliant with standard therapy when enrolled in a trial; studies should include a run-in period of standard care (1-2 weeks) with entry criterion based on change in ulcer size during the run-in phase to exclude those healing because of compliance.
16. Endpoints should be chosen based on the purpose of the intervention; important outcomes include:
  a. incidence of complete closure (defined as skin re-epithelialization without drainage or dressing requirements confirmed at two consecutive study visits 2 weeks apart); closure should be confirmed by an independent source; trial should include at least 3 months follow-up following closure to distinguish actual healing from transient wound coverage; partial healing should not be a primary endpoint except partial healing to facilitate surgical wound closure; if purpose of intervention is something other than healing, endpoints should be pre-defined and validated scoring systems used,
  b. accelerated wound closure (decreased time to healing); monitoring intervals should be sufficiently short to detect meaningful difference in time to closure between treatment groups; ideally all patients would be followed until healing is achieved,
  c. quality of healing (e.g., scarring, contour and feel of healed skin, normalization of skin markings or pigmentation),
  d. quality of wound care (e.g., prevention or cure of infection, reduced pain and/or decreased blood loss with debridement, pain), and
  e. activities of daily living, quality of life, limb salvage, dressing performance.
17. Potential sources of bias include:
  a. selection bias – allocation concealment is important,
  b. performance bias – clearly define standard care; blind outcome assessment; include independent assessment of outcomes,
  c. attrition bias – document reasons for drop-out; plan for drop-outs, including withdrawals due to wound deterioration,
  d. detection bias – define outcomes; follow-up to detect recurrence, and
  e. publication bias – trials may not be published or available in indexed journals.
18. National or formal wound registries should be developed.