# EVIDENCE TABLES

Table 1 Study Characteristics Table

Table 2 Primary Outcomes

Table 3 Secondary Outcomes – Part A

Table 4 Secondary Outcomes – Part B

Table 5 Secondary Outcomes – Part C