# SEARCH STRATEGY

Search Strategy:

--------------------------------------------------------------------------------

1. exp Skin Ulcer/ (31597)
2. exp Foot Ulcer/ (5874)
3. exp Leg Ulcer/ (15666)
4. exp Varicose Ulcer/ (3490)
5. exp Diabetic Foot/ (4864)
6. exp Wound Healing/ (83186)
7. exp Venous Insufficiency/ (5352)
8. or/1-7 (114315)
9. limit 8 to (clinical trial, all or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or clinical trial or controlled clinical trial or meta analysis or randomized controlled trial) (6955)
10. randomized controlled trial.pt. (321315)
11. controlled clinical trial.pt. (83663)
12. random*.ti,ab. (545362)
13. placebo.ti,ab. (132724)
14. or/10-13 (736326)
15. (animals not (humans and animals)).sh. (3590935)
16. 14 not 15 (659693)
17. 8 and 16 (5990)
18. 9 or 17 (8200)
19. limit 18 to (english language and humans and yr=”1995 -Current”) (5646) [a few more important limits]
20. artificial skin.mp. or exp Skin, Artificial/ (1844)
21. 19 and 20 (65)
22. biological dressings.mp. or exp Biological Dressings/ (1128)
23. 19 and 22 (38)
24. exp Negative-Pressure Wound Therapy/ or exp Lower Body Negative Pressure/ or negative pressure.mp. (5422)
25. 19 and 24 (84)
26. exp Collagen/ or collagen.mp. (145508)
27. 19 and 26 (287)
28. exp Silver/ or exp Silver Proteins/ or silver.mp. (37481)
29. 19 and 28 (105)
30. exp Oxygen/ or topical oxygen.mp. (134274)
31. 19 and 30 (51)
32. exp Hyperbaric Oxygenation/ or hyperbaric oxygen*.mp. (10425)
33. 19 and 32 (62)
34. electromagnet*.mp. or exp Electromagnetic Phenomena/ (311999)
35. 19 and 34 (55)
36. exp Platelet-Derived Growth Factor/ or platelet-derived.mp. or exp Growth Substances/ (570646)
37. 19 and 36 (179)
38. exp Platelet-Rich Plasma/ or platelet-rich.mp. (5704)
39. 19 and 38 (66)
40. exp Intermittent Pneumatic Compression Devices/ or pneumatic compress*.mp. or compress* therapy.mp. or compress* pump.mp. (1625)
41. 19 and 40 (130)
42. 21 or 23 or 25 or 27 or 29 or 31 or 33 or 35 or 37 or 39 or 41 (1014)