# THERAPY DESCRIPTIONS AND REFERENCES

## Collagen

The term collagen is applied to a species of chemically distinct macromolecular proteins. The variety of collagen structures is one reason for their diverse roles in ulcer healing. The roles of collagen wound products in ulcer healing may be 1) to act as a substrate for hemostasis, 2) chemotaxis to cellular elements of healing such as granulocytes, macrophages, and fibroblasts, 3) to provide a scaffold for more rapid transition to mature collagen production and alignment, or 4) to provide a template for cellular attachment, migration, and proliferation (Purna 2000). FIBRACOL Collagen-Alginate wound dressing (Johnson and Johnson, New Brunswick, NJ) is an advanced wound care device composed of collagen and calcium alginate fibers. It received FDA approval in August of 1998 for topical use for burns and pressure, venous, and diabetic ulcers. Promogran (Johnson and Johnson) consists of 55% collagen and 45% oxidized generated cellulose. It was approved by the FDA in February of 2002. Promogran is an absorbent open-pored, sterile, freeze-dried matrix used as a topical treatment for chronic ulcers including diabetic and venous ulcers. Promogran is composed of natural materials which physically bind to and inactivate damaging proteases while binding and protecting growth factors. (Cullen 2002).

## Biological Dressings

This category of wound healing therapies consists of biomaterials made from various components of the extracellular matrix (ECM). These acellular matrices are usually derived from animal or cadaver sources and have undergone processing to remove and retain specific elements of the tissue. A commonly used biologically active dressing, the OASIS Wound Matrix (Cook Biotech, West Lafayette, IN), is an ECM product derived from the small intestinal submucosa of pigs. It received FDA 510(k) approval in 2000 and is indicated for the treatment of diabetic ulcers, venous ulcers, and chronic vascular ulcers, in addition to several other dermatologic conditions. This product retains additional active components found within the ECM, including many growth factors (Hodde 2001; Hodde, 2005; McDevitt, 2003) and several elements of ground substance (Hodde, 1996; McPherson, 1998). OASIS becomes incorporated into the ulcer base and is thought to stimulate ulcer healing by providing a structural scaffold and the growth signals important to complex cellular interactions within ulcers, both of which are dysfunctional and contribute to the persistence of chronic ulcers (Hodde, 2007). Lacking a cellular component, these products have the benefit of a long shelf life and are relatively uncomplicated to administer.

## Biological Skin Equivalents (BSE)

These wound-healing therapies are laboratory-derived tissue constructs, designed to resemble various layers of real human skin. They consist of cultured, metabolically active skin cells grown over a scaffold or mesh framework. Two commercially available skin equivalents with FDA approval for treating chronic leg ulcers are Dermagraft and Apligraf. Dermagraft (Advanced BioHealing, Inc., La Jolla, CA) is a dermal tissue substitute that received FDA approval in 2001 for treating diabetic foot ulcers lasting more than 6 weeks. It is formed by culturing human fibroblasts from neonatal foreskin and then growing these fibroblasts over a bioabsorbable polyglactin scaffold. As the cells proliferate in vitro, they secrete important components of the extracellular matrix and a large variety of local growth factors (Naughton, 1997). The product is cryopreserved for storage and delivery, but metabolic activity is regained upon thawing and application to the wound bed (Mansbridge, 1998). Apligraf (Organogenesis, Inc., Canton, MA) is a similar skin substitute made from cultured skin cells but is a bilayer construct that contains both dermal and epidermal components. Apligraf (formerly known as Graftskin, Human Skin Equivalent, and Living Skin Equivalent) received FDA approval in 1998 for chronic venous ulcers and in 2000 was granted further approval for use in diabetic foot ulcers. The human cells in both layers, fibroblasts in the dermis and keratinocytes in the epidermis, are derived from purified cultures of neonatal foreskin. The final metabolically active product has a limited shelf life since it is not cryopreserved but delivered “fresh” to sites for clinical use. Both Apligraf and Dermagraft are metabolically active products thought to increase healing by stimulating fibrovascular ingrowth and epithelialization of host tissues (Ehrenreich, 2006; Límová, 2010). They do not “take” like traditional skin grafts that are meant to replace lost tissue with fully functioning skin, but instead become incorporated into the wound bed and stimulate regrowth of the host's own skin tissue (Ehrenreich, 2006; Límová, 2010; Mansbridge, 1999; Phillips, 2002).

## Keratinocytes

Keratinocyte-based therapies for wound healing exist in a variety of forms. Use of cultured epidermal keratinocytes to treat chronic leg ulcers was first attempted with autologous (Hefton, 1986; Leigh, 1986) and allogeneic (Leigh, 1987) cells in 1986 and 1987, respectively. Since then, different keratinocyte sources have been utilized; the patient's own skin cells, donor cells from cadavers or patients undergoing cosmetic procedures, and bioengineered “immortalized” keratinocytes have all been used. In addition to using different cellular sources, therapies may vary in their use of fresh, cryopreserved, or lyophilized keratinocytes. These products differ in level of metabolic activity and ease of storage and transportation. Furthermore, various application strategies have been attempted for delivering keratinocytes onto wounds, including various suspension mediums (e.g., fibrin sealant), aerosolized sprays, cellular microcarriers, and gels. These products do not act as grafts or serve as permanent skin replacements, as they are rapidly replaced by the host's own keratinocytes (Kaawach, 1991; Burt, 1989; Auböck, 1988). They are thought to work by stimulating proliferation and migration of host epithelium from wound edges through the production of growth factors and other cytokines (DeLuca, 1992; Duinslaeger, 1994; McKay, 1991). Although there have been multiple studies focusing on keratinocyte use in chronic ulcers, currently the only commercially available products in the U.S. are not indicated for use in leg ulcers. However, there are various products on the market, and with ongoing efforts to expand indications and the continuing research focus in this area, an understanding of the current literature on the topic is important in recognizing the limitations and future expectations of keratinocyte-based wound healing

## Platelet-derived wound Healing - Platelet-derived Growth Factors (PDGF)

Human platelet-derived growth factor is a substance naturally produced by the body to help in wound healing. It works by helping to repair and replace dead skin and other tissues, attracting cells that repair wounds, and helping to close and heal the ulcers. (Pierce 1991). Regranex Gel (becaplermin 0.01%, Johnson & Johnson, New Brunswick, NJ) was approved by the FDA in 1997 for the treatment of diabetic foot ulcers. Regranex is a genetically engineered product that mimics PDGF in the body. It is indicated for treating lower-extremity neuropathic ulcersthat extend into the subcutaneous tissue or beyond, but which have an adequate blood supply. It is intended for use as an adjunct to traditional ulcer care strategies, such as initial sharp debridement, daily dressing changes, pressure relief and treatment of infection if present (Label indication 1997).

## Platelet Rich Plasma

Platelet-rich plasma (PRP) is derived from newly drawn whole blood prepared by specialized centrifugation to create plasma having a platelet concentration above baseline. PRPs themselves are have been used in wound healing since 1985 and do not require FDA approval, but centrifuges used to spin whole blood for the creation of PRP do require approval. PRP contains a high level of platelets and a full complement of clotting and growth factors which aid in healing by attracting undifferentiated cells and activating cell division (Lacci 2010). Autologel System (Cytomedix Inc) received FDA approval in September of 2007 and consists of a table top centrifuge (AutoloGel II Centrifuge) and blood access and processing devices.

## Silver

The therapeutic potential of silver has long been recognized, and reports of its use in chronic ulcers have been documented in surgical textbooks as early as 1617 (Klasen, 2000). Due to the broad bactericidal action of silver (Ip, 2006) and the understanding that wound healing is impaired when bacterial levels surpass a particular threshold (Bowler, 2001), multiple silver-based products have been developed to aid in wound healing. These products incorporate silver into topical creams (silver sulfadiazine or Silvadene; King Pharmaceuticals, Bristol, TN) or within various types of dressings, including foams (Contreet Ag; Coloplast, Marietta, GA), hydrocolloids (Contreet H; Coloplast, Marietta, GA), hydrofibers (Aquacel-Ag; Covatec, Skillman, NJ), alginates (Silvercel; Systagenix, Quincy, MA), film polymers (Arglaes; Medline, Mundelein, IL), and a polyethylene mesh with nanocrystalline silver (Acticoat-7; Smith and Nephew, Hull, UK). These products work through the release of reactive silver cations, [Ag^+^], which may disrupt components of the bacterial cell wall, inhibit microbial respiratory enzymes and elements of the electron transport chain, and impair the synthesis and function of DNA and RNA (Atiyeh, 2007). Although these effects are desirable when directed against bacterial and fungal organisms, it is important to recognize the indiscriminant action of silver. Cytotoxicity of various host cells, including keratinocytes and fibroblasts, has been shown to occur from silver, and a delicate balance exists between the beneficial decrease in bacterial burden and the deleterious effects on host cells that can also delay wound closure (Atiyeh, 2007; Poon, 2004; Hollinger, 1996)

## Intermittent Pneumatic Compression Therapy

Intermittent pneumatic compression (IPC) therapy is delivered through inflatable, single-patient-use, garments containing one or more air chambers. Garments are applied to the foot, calf, or calf and thigh and intermittently inflated and deflated with air by means of a powered pneumatic pump to simulate the normal ambulatory calf and foot pump. This action propels the blood of the deep veins towards the heart and benefits the non-ambulatory patient by increasing blood flow velocity in the deep veins and reducing stasis, decreasing venous hypertension, flushing valve pockets, and decreasing interstitial edema (Comerota 2011). Pneumatic compression devices are cleared for marketing under the FDA 510(k) process as Class II devices intended for use in prevention of blood pooling in a limb by periodically inflating a sleeve around the limb. No clinical data was needed for FDA approval since they existed prior to the passage of the Medical Device Amendments of 1976.

## Negative Pressure Wound Therapy (NPWT)

NPWT, also referred to as “vacuum assisted wound closure,” is the process of creating a tightly sealed dressing around a wound and using a suction pump to apply a sub-atmospheric (or “negative”) pressure evenly across the surface in a continuous or intermittent manner (Venturi, 2005). A drainage canister is attached to store fluid collected from wound suction. The first FDA approved, commercially available NPWT product was the Vacuum Assisted Closure™ device (Kinetic Concepts, Inc., San Antonio, TX), introduced to the market in 1995. Since then, the approved indications for its use have continually expanded and currently include diabetic foot ulcers, venous leg ulcers, and pressure ulcers, as well as several non-ulcerative conditions. Other NPWT devices include the Versatile 1™ (BlueSky Medical, Carlsbad, CA), which received FDA approval in 2004, and the Renasys™EZ and Renasys™Go (Smith and Nephew Inc., Largo, FL), approved in 2008 and 2009, respectively. These devices are proposed to enhance wound healing by increasing granulation tissue and local perfusion (Morykwas, 1997), reducing tissue edema, decreasing bacterial load (Morykwas, 1997), and stimulating cellular proliferation via induction of mechanical stress (Olenius, 1993; Saxena, 2004). NPWT may be used as either a primary treatment to achieve complete wound healing, or as a temporary therapy to prepare a wound so that another treatment can be attempted to achieve complete wound closure.

## Electromagnetic Therapy (EMT)

EMT utilizes the electrical field created between large, oppositely charged capacitors or, more commonly, the electrical field that develops from exposure to an oscillating magnetic field (Lee, 1993). There are various potential mechanisms by which EMT may enhance wound healing. Normal human skin has been found to produce a steady state transcutaneous electrical potential (Foulds, 1983) that, upon epithelial disruption, short-circuits to produce an endogenous electrical current (Burr, 1940; Illingworth, 1980; Nuccitelli, 2003; Zhao, 2006) and a resultant electrical field (Nuccitelli, 2003; Zhao, 2006). This wound-induced electrical field has been shown to regulate cell division in wound healing (Song, 2002) and to guide the cellular migration through specific signaling pathways (Zhao, 2006; Fang, 1999). EMT is thought to work by mimicking or enhancing these natural wound-induced electrical fields. No EMT devices have received FDA approval for use in chronic wounds; however, these products have received approval for other indications and are commercially available. Despite the lack of FDA approval, the Centers for Medicare and Medicaid Services (CMS) has deemed EMT to be a reasonable adjuvant treatment for chronic ulcers of diabetic, venous, and arterial etiologies. Because of this, CMS covers the use of EMT for chronic ulcers not responding to standard care.

## Hyperbaric Oxygen Therapy (HBOT)

HBOT involves the use of specialized compression chambers capable of delivering increased concentrations of oxygen (usually 100% O_2_) under elevated atmospheric pressures (usually 1.5-3.0 ATA). This greatly increases systemic levels of oxygen (Sheffield, 1985), achieving arterial oxygen tensions upwards of 2000 mmHg (normally 100 mmHg) and tissue oxygen tensions up to 500 mmHg (normally 55 mmHg) (Gill, 2004). Individual treatment sessions usually last between 45 and 120 minutes and may be done once or twice a day for a total of 10-30 sessions. HBOT is FDA approved for a dynamic list of indications, including wound healing, as deemed appropriate by the Undersea and Hyperbaric Medical Society. Examples of devices include the OxyHeal 1000 Monoplace Hyperbaric Chamber (OxyHeal Health Group, LaJolla, CA) and the Multiplace Hyperbaric Chambers (Makai Marine Industries, Inc., Boca Raton, FL), which received FDA approval in 2005 and 2004 respectively. The role oxygen plays in the process of normal wound healing is complex. Although hypoxia stimulates certain steps in wound healing (Knighton, 1983; Jensen, 1986), and the low oxygen levels in the center of a wound are important in initiating repair (Thackham, 2008), many key aspects of wound healing are oxygen dependent (Gordillo, 2003). These include collagen deposition (Jonsson, 1991), angiogenesis (Hopf, 2005), fibroblast and endothelial cell proliferation (Tompach, 1997), and bacterial clearance (Knighton, 1986; Allen, 1997; Hopf, 1997; Greif, 2000). By raising arterial oxygen tension and the blood-oxygen level delivered to a chronic wound (Rollins, 2006), HBOT is thought not only to supply a missing nutrient but also to promote the oxygen dependent steps in wound healing, to up regulate local growth factors (Thom, 2009), and to down regulate inhibitory cytokines (Thom, 2009). Although thought to be a relatively safe treatment, this delivery of concentrated oxygen in a compression chamber can be complicated by the increased pressure (e.g. ear and sinus barotrauma) or oxygen toxicity (e.g. acute cerebral toxicity and chronic pulmonary toxicity) (Plafki 2000; Sheffield, 2003).

## Topical Oxygen Therapy (TOT)

Similar to HBOT, this category of products aims to promote ulcer healing by correcting the low oxygen levels found within chronic wounds. TOT was developed in an effort to overcome drawbacks inherent with HBOT and works to promote wound oxygenation through a physiological distinct mechanism. While HBOT uses a compression chamber to systemically deliver high O_2_ levels under an elevated atmospheric pressure, TOT works by covering a wound with an airtight bag or chamber and using a portable device to fill the container with concentrated oxygen. Although this results in very slight elevations in local pressure (usually 1.004 - 1.013 ATA), this is far less than the levels reached in HBOT (up to 2.5 - 3.0 ATA) and is not considered truly “hyperbaric” (Feldmeier, 2005). TOT is thought to increase local oxygen levels by simple diffusion of the externally applied gas into superficial wound tissues (Fries, 2005). This method of wound oxygenation may induce angiogenesis through upregulation of specific growth factors (Gordillo, 2008; Scott, 2005) and has been postulated to promote cell motility, extracellular matrix formation, and angiogenesis by correcting hypoxia at the wound center (Gordillo, 2003). Examples of these products include the Hyper-Box Topical Wound Oxygen System (Qualtech House, Gateway, Ireland) that received FDA approval in 2008 and EpiFlo (Ogenix, Corp., Beachwood, OH), most recently approved in 2012 for chronic skin ulcerations due to diabetes and venous stasis. Although CMS covers use of HBOT in some chronic wounds, it does not reimburse for TOT.

## Ozone Oxygen Therapy

Ozone is an oxidizing agent. When ozone molecules are administered via gas or liquid, the ozone is theorized to promote tissue healing. Healthy cells are reported to survive and multiply while defective cells, bacteria, and viruses are destroyed. Ozone has been used to treat medical conditions since the late 19th century, however, there is little known about its safety and efficacy. Ozone can be administered to chronic wounds using a technique known as ozone bagging, a technique in which the effected limb is sealed for up to two hours in a bag containing ozone. Alternatively, ozone-enriched water or vegetable oil may be applied to the skin. Opinions are mixed about the safety of ozone therapy. While some advocates suggest that there is a very low risk of side effects the fact that it is a toxic gas has caused others to question the safety. (Intelihealth, Natural Standard)

## References

Allen DB, Maguire JJ, Mahdavian M, et al. Wound hypoxia and acidosis limit neutrophil bacterial killing mechanisms. Arch Surg. 1997;132:991-6. [pmid: 9301612].
Atiyeh BS, Costagliola M, Hayek SN, Dibo SA. Effect of silver on burn wound infection control and healing: Review of the literature. Burns. 2007;33(2):139-48. [pmid: 17137719].
Auböck J, Irschick E, Romani N, et al. Rejection, after a slightly prolonged survival time, of Langerhans cell-free allogeneic cultured epidermis used for wound coverage in humans. Transplantation. 1988;45:730-7. [pmid: 3258682].
Bowler PG, Duerdon B, Armstrong DG. Wound microbiology and associated approaches to wound Management. Clin Microbiol Rev. 2001;14:244-69. [pmid: 11292638].
Burr HS, Taffel M, Harvey SC. An electrometric study of the healing wound in man. Yale J Biol Med. 1940;12:483-5. [pmid: 21433903].
Burt AM, Pallet CD, Sloane JP, et al. Survival of cultured allografts in patients with burns assessed with a probe specific for Y chromosome. BMJ. 1989;298:915-7. [pmid: 2470446].
Comerota AJ. Intermittent pneumatic compression: physiologic and clinical basis to improve management of venous leg ulcers. J Vasc Surg. 2011;53(4):1121-9. [pmid: 21050701].
Cullen B, Smith R, McCulloch E, Silcock D, Morrison L. Mechanism of action of Promogran, a protease modulating matrix, for treatment of diabetic foot ulcers. Wound Repair Regen. 2002;10(1):16-25. [pmid: 11983003].
DeLuca M, Albanese E, Cancedda R, et al. Treatment of leg ulcers with cryopreserved allogeneic cultured epithelium. Arch Dermatol. 1992;128:633-8. [pmid: 1575526].
Duinslaeger L, Verbeken G, Reper P, Delaey B, Vanhalle S, Vanderkelen A. Lyophilized keratinocyte cell lysates contain multiple mitogenic activities and stimulate closure of meshed skin auto-graft-covered burn wounds with efficiency to that of fresh allogeneic keratinocyte cultures. Plast Reconstr Surg. 1994;98:110-7. [pmid: 8657762].
Ehrenreich M, Ruszczak Z. Update on tissue-engineered biological dressings. Tissue Eng. 2006;12:1-18. [pmid: 16499437].
Fang KS, Ionides E, Oster G, Nuccitelli R, Isseroff RR. Epidermal growth factor receptor relocalization and kinase activity are necessary for directional migration of keratinocytes in DC electric fields. J Cell Sci. 1999;112(12):1967-78. [pmid: 10341215].
Feldmeier JJ, Hopf HW, Warriner RA 3rd, Fife CE, Gesell LB, Bennett M. UHMS position statement: topical oxygen for chronic wounds. Undersea Hyperb Med. 2005;32:157-68. [pmid: 16119307].
Foulds IS, Barker AT. Human skin battery potentials and their possible role in wound healing. Br J Dermatol. 1983;109:515-22. [pmid: 6639877].
Fries RB, Wallace WA, Roy S. Dermal excisional wound healing in pigs following treatment with topically applied pure oxygen. Mutat Res. 2005;579:172-81. [pmid: 16105672].
Gill AL, Bell CN. Hyperbaric oxygen: its uses, mechanisms of action and outcomes. Q J Med. 2004;97:385-95.
Gordillo GM, Roy S, Khanna S, et al. Topical oxygen therapy induces vascular endothelial growth factor expression and improves closure of clinically presented chronic wounds. Clin Exp Pharmacol Physiol. 2008;35:957-64. [pmid: 18430064].
Gordillo GM, Sen CK. Revisiting the essential role of oxygen in wound healing. Am J Surg. 2003;186:259-63. [pmid: 12946829].
Greif R, Akca O, Horn EP, Kurz A, Sessler DI. Supplemental perioperative oxygen to reduce the incidence of surgical-wound infection. N Engl J Med. 2000;342:161-7. [pmid: 10639541].
Hefton JM, Caldwell D, Biozes DG, et al. Grafting of skin ulcers with cultured autologous epidermal cells. J Am Acad Dermatol. 1986;14:399-405. [pmid: 3958255].
Hodde JP, Badylak SF, Brightman AO, Voytik-Harbin SL. Glycosaminoglycan content of small intestinal submucosa: a bioscaffold for tissue replacement. Tissue Eng. 1996;2:209-17. [pmid: 19877943].
Hodde JP, Ernst DM, Hiles MC. An investigation of the long-term bioactivity of endogenous growth factor in OASIS Wound Matrix. J Wound Care. 2005;14(1):23-5. [pmid: 15656461].
Hodde JP, Hiles MC. Bioactive FGF-2 in sterilized extracellular matrix. Wounds. 2001;13:195-201.
Hodde JP, Johnson CE. Extracellular matrix as a strategy for treating chronic wounds. Am J Clin Dermatol. 2007;8(2):61-6. [pmid: 17428110].
Hollinger MA. Toxicological aspects of topical silver pharmaceuticals. Crit Rev Toxicol. 1996;26:255-60. [pmid: 8726163].
Hopf HW, Gibson JJ, Angeles AP, et al. Hyperoxia and angiogenesis. Wound Rep Reg. 2005;13:558-64.
Hopf HW, Hunt TK, West JM, et al. Wound tissue oxygen tension predicts the risk of wound infection in surgical patients. Arch Surg. 1997;132:997-1005. [pmid: 9301613].
Illingworth CM, Barker AT. Measurement of electrical currents emerging during the regeneration of amputated fingertips in children. Clin Phys Physiol Meas. 1980;1:87-9.
Intelihealth.com. Ozone therapy. Available at: http://www.intelihealth.com/IH/ihtIH/WSIHW000/8513/34968/358849.html?d=dmtContent. October 1, 2012.
Ip M, Lui SL, Poon VKM, Lung I, Burd A. Antimicrobial activities of silver dressings: an in vitro comparison. J Med Microbiol. 2006;55:59-63. [pmid: 16388031].
Jensen JA, Hunt TK, Scheuenstuhl H, Banda MJ. Effect of lactate, pyruvate and pH on secretion of angiogenesis and mitogenesis factors by macrophages. Lab Invest. 1986;54:574-8. [pmid: 3702345].
Jonsson K, Jensen JA, Goodson WH III, et al. Tissue oxygenation, anemia, and perfusion in relation to wound healing in surgical patients. Ann Surg. 1991;214:605-13. [pmid: 1953114].
Kaawach WF, Oliver AM, Weiler-Mithoff E, Abramovich DR, Rayner CR. Survival assessment of cultured epidermal allografts applied onto partial-thickness burn wounds. Br J Plast Surg. 1991;44:321-4. [pmid: 1873608].
Klasen HJ. Historical review of the use of silver in the treatment of burns. I. Early uses. Burns. 2000;26:117-30. [pmid: 10716354].
Knighton DR, Halliday B, Hunt TK. Oxygen as an antibiotic. A comparison of the effects of inspired oxygen concentration and antibiotic administration on in vivo bacterial clearance. Arch Surg. 1986;121:191-5. [pmid: 3511888].
Knighton DR, Hunt TK, Scheuenstuhl H, Halliday BJ, Werb Z, Banda MJ. Oxygen tension regulates the expression of angiogenesis factor by macrophages. Science. 1983;221:1283-5. [pmid: 6612342].
Lacci KM, Dardik A. Platelet-rich plasma: support for its use in wound healing. Yale J Biol Med. 2010;83(1):1-9. [pmid: 20351977].
Lee RC, Canaday DJ, Doong H. A review of the biophysical basis for the clinical application of electric fields in soft-tissue repair. J Burn Care Rehabil. 1993;14:319-35. [pmid: 8360237].
Leigh IM, Purkis PE. Culture grafted leg ulcers. Clin Exp Dermatol. 1986;11:650-2. [pmid: 3311493].
Leigh IM, Purkis PE, Navsaria HA, Phillips TJ. Treatment of chronic venous leg ulcers with sheets of cultured allogenic keratinocytes. Br J Dermatol. 1987;117:591-7. [pmid: 2446651].
Límová M. Active wound coverings: bioengineered skin and dermal substitutes. Surg Clin North Am. 2010;90(6):1237-55. [pmid: 21074039].
Mansbridge J, Liu K, Patch R, et al. Three-dimensional fibroblast culture implant for the treatment of diabetic foot ulcers: metabolic activity and therapeutic range. Tissue Eng. 1998;4:403-14. [pmid: 9916172].
Mansbridge JN, Liu K, Pinney RE, Patch R, Ratcliffe A, Naughton GK. Growth factors secreted by fibroblasts: role in healing diabetic foot ulcers. Diabetes, Obes Metabol. 1999;1:265-79.
McDevitt CA, Wildey GM, Cutrone RM. Transforming growth factor beta1 in a sterilized tissue derived from the pig small intestine submucosa. J Biomed Mater Res. 2003;67A:637-40.
McKay IA, Leigh IM. Epidermal cytokines and their roles in cutaneous wound healing. Br J Dermatol. 1991;124:513-8. [pmid: 2064935].
McPherson TB, Badylak SF. Characterization of fibronectin derived from porcine small intestinal submucosa. Tissue Eng. 1998;4:75-83.
Morykwas MJ, Argenta LC, Shelton-Brown EI, et al. Vacuum-assisted closure: a new method for wound control and treatment: animal studies and basic foundation. Ann Plast Surg. 1997;38(6):553-62. [pmid: 9188970].
Natural Standard Professional Monograph. Ozone therapy. 2012. Available at: http://www.naturalstandard.com/databases/hw/ozone.asp?. October 1, 2012.
Naughton G, Mansbridge J, Gentzkow G. A metabolically active human dermal replacement for the treatment of diabetic foot ulcers. Artificial Organs. 1997;21:1203-10. [pmid: 9384327].
Nuccitelli R. A role for endogenous electric fields in wound healing. Curr Top Dev Biol. 2003;58:1-26. [pmid: 14711011].
Olenius M, Dalsgaard C, Wickman M. Mitotic activity in the expanded human skin. Plast Reconstr Surg. 1993;91:213-6. [pmid: 8430134].
Phillips TJ, Manzoor J, Rojas A, et al. The longevity of a bilayered skin substitute after application to venous ulcers. Arch Dermatol. 2002;138:1079-81. [pmid: 12164746].
Pierce GF, et al. Role of platelet-derived growth factor in wound healing. J Cell Biochem. 1991;45(4):319-26. [pmid: 2045423].
Plafki C, Peters P, Almeling M, Welslau W, Busch R. Complications and side effects of hyperbaric oxygen therapy. Aviat Space Environ Med. 2000;71:119-24. [pmid: 10685584].
Poon VK, Burd A. In vitro cytotoxity of silver: implication for clinical wound care. Burns. 2004;30:140-7. [pmid: 15019121].
Purna S, Babu M. Collagen based dressings - A review. Burns. 2000;26:54-62. [pmid: 10630321].
Regranex Product Label. www.accessdata.fda.gov/drugsatfda_docs/label/1997/becaomj121697-lab.pdf. June 15, 2012.
Rollins MD, Gibson JJ, Hunt TK, Hopf HW. Wound oxygen levels during hyperbaric oxygen treatment in healing wounds. Undersea Hyperb Med. 2006;33:17-25. [pmid: 16602253].
Saxena V, Hwang CW, Huang S, et al. Vacuum-assisted closure: microdeformations of wounds and cell proliferation. Plast Reconstr Surg. 2004;114(5):1086-96. [pmid: 15457017].
Scott GF, Reeves RE. Topical Oxygen Alters Angiogenesis-Related Growth Factor Expression in Chronic Diabetic Foot Ulcers. Wound Repair Regen. 2005;13:A4-A27.
Sheffield PJ. Tissue oxygen measurements with respect to soft-tissue wound healing with normobaric and hyperbaric oxygen. HBO Rev. 1985;6:18-46.
Sheffield PJ, Sheffield JC. Complication rates for hyperbaric oxygen therapy patients and their attendants: a 22 year analysis. Proceedings of the Fourteenth International Congress on Hyperbaric Medicine. 2003:312-8.
Song B, Zhao M, Forrester JV, McCaig CD. Electrical cues regulate the orientation and frequency of cell division and the rate of wound healing in vivo. Proc Natl Acad. Sci USA. 2002;99:13577-82. [pmid: 12368473].
Thackham JA, McElwain DLS, Long RJ. The use of hyperbaric oxygen therapy to treat chronic wounds: a review. Wound Repair Regen. 2008;16:321-30. [pmid: 18471250].
Thom SR. Oxidative stress is fundamental to hyperbaric oxygen therapy. J Appl Physiol. 2009;106:988-95. [pmid: 18845776].
Tompach PC, Lew D, Stoll JL. Cell response to hyperbaric oxygen treatment. Int J Oral Maxillofac Surg. 1997;26:82-6. [pmid: 9151158].
Venturi ML, Attinger CE, Mesbahi AN, Hess CL, Graw KS. Mechanisms and clinical applications of the vacuum-assisted closure (VAC) device: a review. Am J Clin Dermatol. 2005;6:185-94. [pmid: 15943495].
Zhao M, et al. Electrical signals control wound healing through phosphatidylinositol-3-OH kinase-γ and PTEN. Nature. 2006;442:457-60. [pmid: 16871217].