# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question #1

We identified three randomized controlled trials, seven longitudinal (cohort or pre-post with repeated cross-sections) studies and 17 cross-sectional studies investigating the role of HR practices in primary care clinics in explaining patient outcomes.

Nine out of eleven of the studies we examined that focused on patient quality of care as an outcome, specifically measured clinicaleffectiveness, thus there is insufficient evidence on the role of provider workplace conditions on access as a quality of care measure. The most frequently studied HR practice for quality of care was workload and while three of the studies suggested that an increase in workload results in lower quality of care, one study also found a positive effect and one found no effect. The other HR practices studied were evaluated less frequently, but there was more consistency in the results across studies: more training (2 studies), shorter hours (2 studies), and computerized systems (3 studies) lead to better quality. Only one study we reviewed examined provider autonomy or flexibility and found mixed effects on quality of care scores; this is insufficient evidence for the role of autonomy. Overall, these results are suggestive but make it difficult to make strong conclusions about the role of HR practices on patient quality of care.

We identified three studies in our review that explicitly examined the role of human resource practices on patient safety in the primary care setting. While these were relatively well designed studies, more studies are needed. Because only two studies examined workload, one of which also examined autonomy, and the third study examined computerized systems, there is insufficient evidence to answer our key question about how HR practices influence patient safety.

We identified 17 unique studies that investigated how HR practices influence patient satisfaction with either the provider or the clinic. We found mixed evidence on the role of provider skills (MD vs. NP/PA) on patient satisfaction; two studies found no effect and two studies found a negative effect of skills. We found mostly no effect of provider workload on patient satisfaction (3 studies), with the exception of one Norwegian study reporting that a longer listsize resulted in greater patient satisfaction. All four of the studies that examined provider training and all three that examined provider work hours found that they had no effect on patient satisfaction. Thus, there was suggestive evidence that training and work hours do not effect patient satisfaction, but again because of the lack of well-designed studies, we cannot make strong conclusions about these findings. Similarly, we conclude that there is inconsistent evidence on the role of skills and workload. We identified no studies that looked at how electronic medical records or computerized systems affect patient satisfaction.

### Key Question #2

The available literature provides low strength or insufficient evidence for varied components of organizational culture including PCMH, team-based care, care environment, and clinic values and their effect on outcomes highlighted in our key questions. Such evidence does not permit conclusions with regard to quality of care, patient safety, and patient satisfaction.

Our report on the influence of organizational culture parallels a systematic review published by the Cochrane Collaboration in 2011 titled “The Effectiveness of Strategies to Change Organizational Culture to Improve Healthcare Performance.”73 The report considered any strategy intended to change organizational culture in order to improve healthcare performance. While the Cochrane review identified similar outcomes of interest (quality of care, patient satisfaction, organizational performance, and provider outcomes), no studies met their inclusion criteria. The Cochrane review was not limited to ambulatory primary care settings, but sought only studies meeting quality criteria developed by the Cochrane Effective Practice and Organisation of Care Group (EPOC). While our review used a similar definition of organizational culture, we included a broader range of methodologies.

The 2003 AHRQ review4 looked at the effect of organizational culture on measures of patient safety. The authors discussed difficulty in examining the affect of cultural factors on patient outcomes rooted in the broadly defined concepts ranging from cultural norms, to more concrete practice interventions. Their report concluded that despite multiple studies using diverse study methodologies conducted in different workplace settings, there was insufficient evidence related to the effect of organizational factors on patient safety. Similarly, our report found insufficient evidence across diverse constructs of organizational culture to draw conclusions related to quality of care, patient safety, and patient satisfaction.

Although there has been research on the effect of physical environment (notably lighting, color, auditory stimuli, and temperature) on workplace performance, much of that work has been done in industrial settings and what has been done in healthcare has largely focused on hospitals.4,74 We found few studies that examined the effect of physical environment in primary care clinics. No study attempted to isolate any one component of the physical environment. Reported outcomes focused on patient self-report of anxiety and satisfaction with no objective measures of patient safety, quality of care, or provider performance.

### Key Question #3

Consistent with more thorough systematic reviews of the literature examining how workplace conditions affect providers’ stress, job satisfaction, etc., among the studies in our review that also examined provider outcomes, we found that greater workloads and less control over work tasks resulted in greater provider stress, burnout, and job satisfaction. One study we examined found that electronic medical records did not result in greater provider stress.

The relationships between workplace conditions, provider outcomes, and patient outcomes are complex and dynamic in such a way that not only are the effects felt at many levels (provider, patient, healthcare system), but also they create a cycle of reinforcing behaviors and outcomes. There are several potential policy interventions at the various levels that might positively influence provider wellbeing. In this study, we focus on studies that shed light on possible workplace interventions (as opposed to provider self-care or higher-order system level interventions) that will ultimately impact patient outcomes. Such changes to workplace conditions will likely [underlined: also] influence provider outcomes. However, we present these results as only suggestive, but consistent with other literature, including systematic reviews, that has established evidence on the intermediate link between workplace conditions and provider outcomes.

## RECOMMENDATIONS FOR FUTURE RESEARCH

As shown in Tables 1, 3, and 4, there is little research that investigates the effects of working conditions on patient safety, which we measure specifically as medication errors, in the primary care setting. More generally, more well-designed studies are needed to replicate the few that have been conducted. For example, all ten of the studies we reviewed that investigated the role of workload were cross-sectional studies. While undertaking randomized controlled trials may be impractical, well-designed cohort studies or other pre-post designs will allow for more convincing evidence on the causal effect of the workplace conditions.

Additionally, there is a need for research that looks rigorously at the interdependent role of human resource practices (such as hours worked, provider autonomy, and electronic medical records), organizational culture, and physical environment in explaining patient outcomes in primary care settings. Research on the role of workplace conditions in explaining worker productivity, turnover, burnout, and other employee outcomes suggests that many of these characteristics are “bundled”75–77 and complementary. For example, a clinic that rolls out team-based care will likely also have other workplace conditions and workflow designs that facilitate teamwork, such as electronic medical records or an organizational culture that values teamwork. However, none of the studies we reviewed investigated how the “system” or complete workplace environment affected patient outcomes. Studying the effect of one HR practice, such as electronic medical records or teams, ignores the fact that these practices occur within a larger organizational setting with a particular organizational culture and related or complementary practices. Thus, isolating the marginal effect of just one of these practices is empirically difficult. Larger scale studies that are able to compare more clinics or hospitals and more fully characterize the workplace are needed.

The development of or more consistent use of construct valid measures of both working conditions and patient or provider outcomes in the primary care settings is needed to make comparisons across studies easier. Future research should incorporate randomized controlled trials or high quality quasi-experimental designs.

## CONCLUSIONS

Overall, the studies we reviewed suggest that in primary care settings:

- a lighter provider workload/shorter work hours, more provider training, and computerized systems result in higher patient quality of care
- provider training and work hours have no effect on patient satisfaction.

We find mixed evidence on the effect of provider skill levels and workload on patient satisfaction. We identified very few studies in our review that explicitly examined the role of workplace conditions on patient safety or the role of the physical environment on patient outcomes in the primary care setting, thus more studies are needed. Several workplace conditions have been insufficiently studied and thus there is no evidence on how these practices matter in ambulatory care settings: the effect of computerized systems, provider autonomy and teams on patient satisfaction; and the effect of autonomy on quality of care. We also note that the lack of evidence does not necessarily imply the lack of a relationship; we also do not explore other possible hypotheses, including the possibility that workplace conditions affect healthcare providers, but healthcare providers are still able to do their jobs adequately such that patients are not affected.

The available literature provides low strength or insufficient evidence for varied components of organizational culture including PCMH, team-based care, care environment, and clinic values and their effect on outcomes highlighted in our key questions. Such evidence does not permit conclusions with regard to quality of care, patient safety, and patient satisfaction.

We found two studies that focused on the effect of physical environment in primary care clinics. No study attempted to isolate any one component of the physical environment. Reported outcomes included self-report of anxiety and satisfaction with no objective measures of patient safety or quality of care.

Consistent with more thorough systematic reviews of the literature examining how workplace conditions affect providers’ stress, job satisfaction, etc., among the studies in our review that also examined provider outcomes, we found that greater workloads and less control over work tasks resulted in greater provider stress, burnout, and less job satisfaction. One study we examined found that electronic medical records did not result in greater provider stress.