# RESULTS

## LITERATURE FLOW

Figures 3–5 detail the exclusion criteria and the number of references related to each of the key questions. Separate searches were conducted for the human resource practices components of staffing and work flow. For the staffing search, we identified 1008 abstracts and excluded 913. Of 95 full text articles reviewed, we included 14. For the work flow search, we identified 1,581 abstracts and excluded 1,487. Of 94 full text articles reviewed, we included 9. Four articles were added from our hand search of reference lists resulting in a total of 27 references included for human resource practices (Key Question #1).

Figure 3 Literature Flow Diagram – Human Resource Practices Studies

Figure 4 Literature Flow Diagram – Organizational Culture Studies

Figure 5 Literature Flow Diagram – Physical Environment Studies

We identified 541 abstracts pertaining to organizational culture. After excluding 497, we reviewed 44 full text articles and included 2. One article was added from the specific team-based care search and 6 articles were added from hand searching resulting in a total of 9 included references.

The physical environment search resulted in 49 abstracts. We excluded 46 and reviewed the full text of 3 articles. All 3 were excluded. The 2 articles included in the report were added after hand searching.

## KEY QUESTION #1 How are human resource practices, such as skill levels, training, workload, hours worked, autonomy, and electronic medical records/systems, associated with patient outcomes?

a. quality of care (access and effectiveness)
b. safety (medication errors)
c. patient satisfaction (with provider, with clinic/practice)

Twenty-seven studies (12 set in the US, 13 set in Europe, and 2 set outside of the US/Europe) met inclusion criteria.6, 32–57 We summarize these studies in Appendix D, Tables 1–3. In Table 1, we present an overall summary of studies by HR practice and patient outcome studied. We reviewed studies that investigated the following HR practices a) skills (measured as MD versus NP or PA skill level), b) training (different training interventions to increase patient communication, visit efficiency or clinical effectiveness), c) workload (measured most often as the provider’s listsize), d) hours (measured as either full time versus part time work, as a continuous measure of hours worked, or hours worked after being on-call), e) autonomy (provider report of control over work tasks), and f) electronic medical records (EMR) system or other computerized system (e.g., referral system). We discuss the main findings for each HR practice below.

Table 1 Human Resource Practices Studies by HR Practice Studied and Patient Outcome Studied

| | Quality of Care | Patient Safety | Patient Satisfaction
HR Practice Studied | First Author, Year | Clinical Effectiveness or Access | Reduced Errors^1^ | With Provider | With Practice or Care
Skills | Caldow 2006^32^ | n/a | n/a | | ↔
Skills | Dierick-van Daele 2009^33^ | n/a | n/a | ↔
Skills | Laurant 2008^34^ | n/a | n/a | ↓
Skills | Mundinger 2000^*,35^ | n/a | n/a | ↔
Skills | Roblin 2004^*,36^ | n/a | n/a | ↓ | ↔
Training | Castro 2009^*,37^ | | | ↔
Training | Edwards 2004^38^ | | | ↔
Training | Goulet 2007^39^ | ↑
Training | Haas 2006^*,40^ | | | ↔
Training | Zabar 2010^*,41^ | ↑ | | ↔
Workload | Campbell 2001^42^ | ↓
Workload | Campbell 2005^43^ | ↓
Workload | Carlsen 2006^44^ | | | ↔
Workload | Dong 2010^45^ | | ↑
Workload | Grytten 2009^46^ | | | | ↔
Workload | Linzer 2009^*,6^ | ↔ | ↔
Workload | Luras 2007^47^ | | | ↑ | ↑
Workload | Magan 2011^48^ | ↓
Workload 2 | Nyweide 2009^*,49^ | ↑
Workload | Salisbury 2010^50^ | | | ↔ | ↔
Hours | Fairchild 2001^*,51^ | ↓ | | ↔
Hours | French 2001^52^ | | | ↔ | ↔
Hours | Parkerton 2003^*,53^ | ↓ | | ↔
Autonomy | Linzer 2009^*,6^ | ↔ | ↑
Autonomy | McKinstry 2007^54^ | | | | ↓
EMR | DesRoches 2008^*,55^ | ↑ | ↑
EMR | Feldstein 2010^*,56^ | ↑
EMR 3 | Weiner 2009^*,57^ | ↑
Total Studies 4 | | 12 | 3 | 14 | 7

* Indicates the study was conducted in the U.S.

1 This outcome has been reverse coded in this table so that a positive effect (up arrow) indicates the study found a reduction in medical errors.

2 Measured as Medicare caseload in this study.

3 EMR refers to an electronic referral system in this study.

4 This is a count of the total number of unique studies for each patient outcome. There are 27 total studies that evaluate at least one HR practice and one patient outcome. An “up” arrow indicates that the presence/implementation of an HR practice (training, autonomy, EMR) or the increase in a practice (skill level, workload, or hours) was associated with higher quality of care, more reduced errors (i.e., better patient safety), or greater patient satisfaction. A “down” arrow indicates that increasing/implementing the HR practice resulted in lower quality of care, fewer reduced errors, or less patient satisfaction. The ↔ arrow indicates that no significant association was found.

### Skills

Two US and three European studies were included that focused on how provider skill level (MD vs. NP/PA) influenced patient satisfaction. Overall, the evidence was inconsistent on the effect of provider skill level on patient satisfaction. One large cross-sectional study of over 26,000 Kaiser Permanente patients in Georgia found that patients were about 15 percent (p<0.05) more likely to be satisfied with the provider interaction received when seeing a PA/NP instead of an MD, but found no significant difference in satisfaction with care by skill level of the provider,36 as did one smaller scale cross-sectional study set in the Netherlands.34 However, two studies where patients were randomly assigned to either an MD or an NP found no evidence of differences in patient satisfaction by skill level.33,35 We identified one VA study that examined patient satisfaction scores from 1.6 million veterans seen in 21 VISNs and reported aggregate changes in patient satisfaction over time by VISN, but the authors did not report these results stratified by skill level except for three specific VISNs where increased when more NP/PAs were hired,58 so we were unable to include this study in our review. Overall, the evidence was inconsistent on the effect that provider skill level has on patient satisfaction. We do note that the two randomized control studies found no effect. Following the 2003 AHRQ report, we did not review studies that examined the effect of skill levels on patient quality of care or patient safety as it is widely accepted that medical school or more training increases quality of care.4

### Training

Five studies (three US, one Canadian, and one European) were included that evaluated the effectiveness of a training intervention on patient satisfaction and quality of care. All four that examined patient satisfaction found no effect of various training programs. These training programs included training on how to effectively structure visits,40 communication skills workshops,41 shared decision making and risk communication training,38 and a provider report of having received cultural competence training.37 The latter study was not an analysis of the intervention and only examined correlations between provider report of having received cultural competence training and patient satisfaction (i.e., no pre/post analysis).37 However, two studies (one US and one Canadian study) found a positive effect of training (communication skills workshop and a remedial professional development program) on clinical effectiveness measured from audits of patient charts for guideline concordant care.39,41 Overall, we find some evidence that training might improve clinical effectiveness, but little evidence that it affects patient satisfaction. There were no studies included in our review that examined the effect of training on patient safety, in this case medication errors; however, there is a large literature investigating the role of training on patient safety in hospital settings (e.g., surgical training) that has found, in general, that more training improves patient safety (e.g., Wachter, 2004;2 Shapiro et al., 2004^59^).

### Workload

Ten studies were included that investigated how provider workload affects patient outcomes. Three of the four studies (all European) that specifically examined patient satisfaction found no correlation between workload and patient satisfaction. However, the measures of patient satisfaction in two of these studies included satisfaction with wait time or ability to get an appointment.46,50 Only one study found a positive correlation between provider workload and patient satisfaction measured specifically as satisfaction with the care received.47 Thus, we conclude that there is little evidence that workload affects patient satisfaction with the provider, though it might influence satisfaction with the ability to get an appointment.

Three of the five studies (one US and three European) found that workload negatively affects quality of care, measured as guideline concordant care for management of chronic conditions,42 access to provider,43 and rates of ambulatory care sensitive hospitalizations.48 One study reported that care quality scores were not significantly different for providers with high time pressure or for those who worked in a “chaotic office.”6 The fifth study reported that greater Medicare caseloads were needed to obtain higher rates of patients getting preventive care screening.49 However, as that study uses a different measure of workload (which may arguably not be a good proxy for workload), we conclude that there is some evidence suggesting that higher workloads negatively influence quality of care.

Finally, two studies (one in the US and one in China) investigated workload and patient safety. The US study surveyed almost 1,800 patients across 119 clinics in 5 urban and rural area and found that a greater workload (time needed per patient divided by the time allotted per patient) had no effect on non-medication treatment errors assessed from chart audits.6 However, a large study of over 20,000 prescriptions written from 680 primary care clinics in rural China found that physicians with greater workloads (patient visits/month) were about 70 percent more likely to prescribe 5 or more drugs per patient than those with lighter workloads.45 Thus, given that these studies are not representative and yield conflicting findings, we conclude that there is insufficient evidence about the role of workload on patient safety. However, as discussed in the previous paragraph, two studies found no effect of workload on guideline concordant care and one found no effect on ambulatory care sensitive hospitalizations, all of which could be considered measures of patient safety.

### Hours

Three studies (two US and one European) were included that investigated how provider work hours affects patient satisfaction and quality of care. All three studies found no effect of providers’ work hours on patient satisfaction; regardless of whether hours were measured as full time vs. part-time (less than 30 hours per week),51 as a continuous measure of appointment hours,53 or designated as hours surrounding “on call” versus “off call” duty.52 However, two of these studies also examined the effect of hours on patient quality of care and found that providers who work fewer hours were more likely to be compliant with guidelines for preventive care screening and management of a chronic disease.51,53 Thus, based on these three studies, our review suggests that while provider’s work hours may not have influenced patient satisfaction, there was some preliminary evidence that longer work hours may have negatively affected quality of care provided. We note that most of these studies meet few of the low risk of bias quality criteria described in the Appendix. There were no studies included in our review that investigated hours and patient safety (in this case, medication errors), though there is a large literature examining the effect of hours worked among nurses, residents and in hospital settings (see AHRQ report4).

### Autonomy

Two studies (one US and one European) were included that investigated provider reports of autonomy, or provider control over work tasks, and patient outcomes. The Linzer et al., study (described above),6 found that providers who reported greater control (based on a 14 item scale that was then dichotomized) did not have greater quality “scores” based on chart audits assessing their management of chronic conditions but did have lower error “scores” based on chart audits assessing their missed treatment opportunities, inattention to behavioral factors and guideline non-adherence. A study based in Scotland found that patients were less satisfied with how they were treated by staff and wait time for visits where the provider reported greater control of work.54 Although these two studies are suggestive, this is insufficient evidence to draw conclusions about the role of job autonomy on patient outcomes.

### Electronic Medical Records

Three studies (all US) were included that investigated EMRs or other computerized systems that affected how providers do their jobs. All three studies found that EMR systems improved quality of care by alerting providers to critical lab values, assisting providers to provide preventive care, order lab work, tests, or specialty referrals.55–57 One study also found evidence that an EMR system that gave warnings and clinical decision support was more effective in helping providers prevent drug allergies or dangerous medication interactions over more basic systems without those capabilities.55 While these three studies suggest that EMR systems have improved patient quality of care, one study relied on provider reports of how the system aided work, as opposed to more objective measures.55 One large study utilized panel data methods to assess specialty referrals before and after an electronic medical referral system was put in place,57 but the other two studies relied on cross-sectional or cohort analysis. Thus, the evidence is suggestive that EMR systems improve patient quality, but more intervention analyses should be done and there is insufficient evidence on how EMR systems affect patient satisfaction.

### Pay for Performance

One theoretical component of workplace conditions is the practice of Pay for Performance (P4P) where providers are partially compensated with incentive payments based on quality of care. A large body of literature focused on P4P exists, but we discuss two more recent systematic reviews without doing a systematic review of the P4P literature.60,61 Although Christianson et al.60 reported improvement in select quality measures, they also concluded that the role of financial incentives for providers in quality improvement is unclear. The authors underlined variation in targeted outcomes, criteria for incentives, and questions based on provider reactions to incentives as topics for further research. A 2010 review of one hundred twenty-eight evaluation studies61 made similar conclusions. Thus, while there may be some evidence of the effectiveness of P4P systems, two recent systematic reviews conclude that there is too much variation in the evidence, study designs, and provider attributes to make clear conclusions about the effect of P4P on patient outcomes.

#### Summary of Findings

We identified three randomized controlled trials, seven longitudinal (cohort or pre-post with repeated cross-sections) studies, and 17 cross-sectional studies investigating the role of HR practices in primary care clinics in explaining patient outcomes.

Nine of eleven studies we examined that focused on patient quality of care as an outcome, specifically measured clinical effectiveness, thus there is insufficient evidence on the role of provider workplace conditions on access as a quality of care measure. The most frequently studied HR practice for quality of care was workload and, in general, the evidence suggests that an increased workload results in lower quality of care. However, the only two US studies found either no effect6 or a positive effect.49 Furthermore, all of the workload studies were cross-sectional and often were not low risk of bias studies. The other HR practices studied were evaluated less frequently, but there was more consistency in the results across studies: more training (2 studies), shorter hours (2 studies), and computerized systems (3 studies) lead to better quality. Only one study we reviewed examined provider autonomy or flexibility and found mixed effects on quality of care scores; this is insufficient evidence for the role of autonomy. Overall, these results are suggestive but make it difficult to make strong conclusions about the role of HR practices on patient quality of care.

We identified three studies in our review that explicitly examined the role of workplace conditions on patient safety, measured as medication errors, in the primary care setting. While these were relatively well designed studies, more studies are needed. Because only two studies examined workload, one examined autonomy and one examined computerized systems, there is insufficient evidence to answer our key question about how HR practices influence patient safety.

We identified 17 unique studies that investigated how HR practices influence patient satisfaction with either the provider or the clinic. We found mixed evidence on the role of provider skills (MD vs. NP/PA) on patient satisfaction; two studies found no effect and two cross-sectional studies found a negative effect of skills. We also found mixed evidence on the role of provider workload with one study finding a positive effect and two finding no effect. All four of the studies that examined provider training and all three that examined provider work hours found that they had no effect on patient satisfaction. Overall, there is suggestive evidence that training and work hours do not effect patient satisfaction, but again, because of the lack of studies, we cannot make strong conclusions about these findings. Similarly, we conclude that there is inconsistent evidence on the role of skills and workload. We identified no studies that looked at how computerized systems affect patient satisfaction.

#### Quality of Evidence for Key Question 1

Quality of randomized and non-randomized trials was assessed as described in the Methods section. Items considered in assessing the quality of randomized trials are presented with the study description (Appendix D, Tables 1–3). Figure 6 depicts the percent of the non-randomized trials that met the criteria for each quality dimension assessed.

Figure 6 Study Quality of Human Resource Practices Non-Randomized Studies

Notes: There were 24 (out of 27) non-RCT studies examining HR practices and patient outcomes. Only 4 of these studies included intervention (and thus were evaluated on that dimension). The numbers on each bar indicate the number of studies that either met the study quality criteria (dark gray) or did not (light gray).

We evaluated the strength of evidence for the workplace conditions and patient outcomes for which we had at least three studies (Table 2). Strength of evidence overall was low for patient satisfaction and provider skills, workload, and hours; and for quality of care and provider workload and electronic medical records. Most of the evidence was rated high or moderate on risk of bias due to the lack of many well-designed RCTs or observational studies that address potential biases. There was also inconsistent measurement of both the workplace condition constructs and the patient outcome constructs, which made comparisons across studies difficult. There was insufficient evidence for patient safety and all workplace conditions, quality of care and training and hours, and patient satisfaction and EMR. Additionally, there was insufficient evidence on provider autonomy and all patient outcomes.

Table 2 Human Resource Practices – Strength of Evidence for Key Outcomes

Workplace Condition & Patient Outcome (#of studies) | Domains of Strength of Evidence | | | | | Overall Strength of Evidence (SOE) (effect if consistent)
Workplace Condition & Patient Outcome (#of studies) | Risk of Bias | Consistency | Directness | Precision | Other Notes | Overall Strength of Evidence (SOE) (effect if consistent)
Patient Satisfaction & Provider Skills (5) | High | Inconsistent | Direct | Imprecise | | Low SOE
Patient Satisfaction & Provider Training (4) | High | Consistent | Direct | Precise | Training is measured inconsistently across studies | Low SOE (positive effect)
Patient Satisfaction & Provider Workload (4) | Moderate | Consistent | Indirect | Precise | Workload is often measured as “listsize” | Low SOE (no effect)
Patient Satisfaction & Provider Hours (3) | High | Consistent | Direct | Precise | | Low SOE (no effect)
Quality of Care & Provider Workload (5) | High | Inconsistent | Indirect | Precise | Workload is often measured as “listsize” | Low SOE
Quality of Care & Electronic Medical Records (3) | Moderate | Consistent | Indirect | Precise | EMR/computerized systems are measured inconsistently across studies | Low SOE (positive effect)

## KEY QUESTION #2 How are other working conditions, such as organizational culture or physical environment, associated with patient outcomes?

a. quality of care (access and effectiveness)
b. safety (medication errors)
c. patient satisfaction (with provider, with clinic/practice)

### Organizational Culture

Nine studies met inclusion criteria.6,62–69 Six studies were conducted in the United States and three in Canada. We summarize study characteristics in Appendix D, Table 7. We reviewed studies that examined the following four organizational culture components: a) patient-centered medical homes (PCMH) (patient-centered approach to care management and coordination through a practice based care team), b) team-based care (multi-disciplinary care centered around the primary care physician to facilitate communication among care team members), c) care environment (environment and culture focused on delivering care to a specific demographic of the population), and d) clinic values (perceptions of how organizational values line up with personal values of providers). Table 3 provides an overview of the distribution of studies by reported outcomes (quality of care, patient safety, patient satisfaction, and provider outcomes).

Table 3 Organizational Culture Studies by Practice Studied and Patient Outcome Studied

| | Quality of Care | Patient Safety | Patient Satisfaction
Practice Studied | First Author, Year | Clinical Effectiveness or Access | Reduced Errors | With Provider | With Practice or Care
Care environment | Bean-Mayberry 2003^*,62^ | | | | ↑
Clinic Values | Linzer 2009^*,6^ | ↑
PCMH | Gilfillan 2010^*,63^ | ↑
PCMH | Reid 2009^*,64^ | ↑ | | ↑ | ↑
Team-based care | Adam 2010^*,65^ | ↔ | | | ↔
Team-based care | Boyd 2009^*,66^ | | | | ↑
Team-based care | Chomienne 2011^67^ | ↑
Team-based care | Hogg 2009^68^ | ↑
Team-based care | Sellors 2003^69^ | | ↔
Total studies 1 | | 6 | 1 | 1 | 4

* Indicates the study was conducted in the U.S.

1 This is a count of the total number of unique studies for each outcome. There are 8 total studies that evaluate at least one organizational culture practice and one patient outcome. An “up” arrow indicates that the increase in/implementation of an organizational culture practice was associated with higher quality of care, more reduced errors (i.e., better patient safety), or greater patient satisfaction. A “down” arrow indicates that increasing/implementing the organizational practice resulted in lower quality of care, fewer reduced errors, or less patient satisfaction. The ↔ arrow indicates that no significant association was found.

#### PCMH

Two pre-post observational studies reported quality of care outcomes based on the organizational culture component of PCMH.63,64 Both studies showed improvements in quality of care at clinics where PCMH was implemented. Although Reid et al. found no improvement in hospitalization rates for PCMH clinics compared with usual care, PCMHs resulted in significant improvements in hospitalizations for ambulatory care sensitive conditions (ACSC).64 The second study demonstrated significant improvement in hospital admission and readmission rates for PCMH clinics against modeled controls.63 Reid et al.64 also found that patient satisfaction with provider (quality of interaction, shared decision making, coordination of care, access to provider) and care (patient involvement, goal setting/tailoring) increased after the implementation of PCMH. Although there were only two studies reviewed, both employed a pre-post observational design and suggested that PCMH improved quality of care and patient satisfaction.

#### Team-based Care

Five studies reported outcomes for the primary care cultural component of team-based care.65–69 Three studies evaluated the effect of team based care on quality of care outcomes.65,67,68 Two of these studies, including one randomized controlled trial,68 found that team based care significantly increased quality of care, measured as chronic disease management and preventive care with the use of team care68 and patient rated quality of life.67 However, the third study, a case-control design, demonstrated no change in hospitalizations or emergency room (ER) visits.65 Two studies evaluated patient satisfaction with team-based care65,66 and found mixed results. One cross-sectional study showed no improvement in patient satisfaction,65 whereas the randomized controlled trial study found a two-fold increase in patient rating of chronic care for team-based guided care versus usual care.66 Finally, one study randomized 48 physicians and their patients to receive pharmacists’ consultations or usual care and found that face-to-face patient-pharmacist consultations identified at least one drug problem in 79 percent of the intervention population with no data provided for control physicians.69 Overall, these studies present contradictory evidence making it difficult to make conclusions about how effective team-based primary care is for improving quality of care or patient satisfaction. We identified only one study that evaluated the effect of teams on patient safety in the ambulatory care setting,69 but comparison data were not presented in this study.

#### Care Environment

We reviewed one cross sectional study that reported patient satisfaction with care based on the care environment.62 Specifically, among women using the Veterans Health Administration (VHA) system of care, attending a women’s clinic was a significant positive predictor for all measures of patient satisfaction with care (privacy and comfort, communication, complete care, follow-up, receiving care, overall) when compared with usual primary care clinics. This one study is insufficient to make conclusions about the role of the care environment on patient satisfaction. We identified no studies that investigated the relationship between the care environment and quality of care or patient safety.

#### Clinic Values

One cross-sectional study looked at clinic values in relation to provider satisfaction, and quality of care.6 The study found a positive association between clinical values such as quality emphasis, information and communication emphasis, organizational trust, workplace cohesiveness, and values alignment and total quality measured by diabetes care, hypertension management, and preventive care. Thus, there is insufficient evidence on the role of clinic values or norms in explaining patient outcomes.

### Summary of Findings for Organizational Culture

There is limited evidence from two pre-post quasi-experimental studies on PCMH as a primary care cultural component. These studies reported positive effects of PCMHs on quality of care, and the one study that evaluated the effect of PCMH on patient satisfaction found a positive effect. We conclude that there is suggestive evidence that PCMHs increase quality of care, but in general insufficient evidence on the effect of PCMHs on patient outcomes. PCMH studies were assessed to have a high risk of bias meeting only two of five quality criteria for non-randomized studies as described in the methods section.

Limited data from five studies provided inconsistent evidence that team-based care improved quality, patient safety, or patient satisfaction. Two studies found positive effects of team-based care and patient quality of care, however one of these was a high risk of bias study. The other study on quality of care and teams found no effect. Thus, while the evidence is suggestive that team-based care improves patient quality of care, more well-designed studies are needed. Results for patient satisfaction were unclear as one cluster-randomized controlled trial with a low risk of bias reported that patients seen by guided care teams had twice greater odds of rating chronic care highly66 and one cross-sectional study found no significant association. Finally, results for patient safety or medication errors are inconclusive for team-based care due to limited evidence from one randomized controlled trial with a high risk of bias69 that did not report comparison effects.

Evidence for the effect of care environment on patient satisfaction is also unclear. One cross sectional study which met one of four quality criteria for non-randomized controlled trials showed higher patient satisfaction with care among women attending a women’s clinic at the Veterans Health Administration. Related studies investigating the effect of “clinic values” and quality of care suggested a positive correlation with quality of care. However, validated measures of the care environment or clinic values are needed in order to make comparisons across studies.

### Strength of Evidence for Organizational Culture

The strength of evidence for the affect of PCMH on quality of care is low primarily due to a high risk of bias, and inconsistencies in reported effect size. The studies directly related PCMH interventions to quality of care without surrogates, but a rating of precision was not applicable due to lack of pooled outcomes. Only one study reported on patient satisfaction with PCMH therefore the body of evidence is insufficient for strength assessment.

The strength of evidence for the effect of team-based care on quality of care is low due to studies with a high risk of bias, inconsistencies in the reported effect sizes, and indirect reporting using surrogate measures for quality of care. Again, a rating of precision was not applicable due to lack of pooled outcomes. Only one study reported on patient safety with team-based care and therefore the body of evidence is insufficient. The strength of evidence for the effect of team-based care on patient satisfaction is low due to studies with a high risk of bias, an indirect link to patient satisfaction, and inconsistent effect sizes. A measure of precision was not applicable. The evidence for the effect of care environment or clinic values on quality of care or patient satisfaction is insufficient as each component of organizational culture included only one study.

Figure 7 Study Quality of Organizational Culture Non-Randomized Studies

Notes: There were 6 (out of 9) non-RCT studies examining organizational culture practices and patient outcomes. Only 5 of 6 studies provided outcomes based on interventions. The numbers on each bar indicate the number of studies that either met the study quality criteria (dark gray) or did not (light gray).

### Physical Environment

Two studies met inclusion criteria70,71 are summarized in Appendix D, Table 12. One study was conducted in the United States71 and one was conducted in the United Kingdom (UK).70 We also present data from a systematic review of patient satisfaction with electronic health record (EHR) use in examination rooms.

Table 4 Physical Environment Studies by Patient Outcome Studied

| Quality of Care | Patient Safety | Patient Satisfaction
First Author, Year | Clinical Effectiveness or Access | Reduced Errors | With Provider | With Practice or Care
Arneill 2002 71 | ↑^*^ | | | ↑^**^
Rice 2008 70 | | | | ↑

* Study measured “perceived” quality of care;

** Study measured “perceived” comfort in environment

An “up” arrow indicates that “better” physical environment was associated with higher quality of care or greater patient satisfaction

The UK study evaluated patient anxiety and satisfaction and patient-doctor communications before and after relocating to a new clinic facility.70 Enhanced environmental features of the new clinic included lighting, sound, space, privacy, furnishings, and artwork. Patients reported significantly less anxiety both before and after a provider consultation in the new facility (Table 5). They also preferred the new reception/waiting area and consultation rooms and rated satisfaction with doctor-patient communication higher in the new facility.

Table 5 Physical Environment Outcomes70

Variable | Phase 1 (pre-move) | Phase 2 (post-move) | Significance
STAI Pre-consultation^a^ | 11.7 | 10.9 | p<0.001
STAI Post-consultation^a^ | 10.5 | 10.1 | p=0.03
Reception/Waiting Area Rating^b^ | 33.3 | 39.8 | p<0.001
Consultation Room Rating^c^ | 23.0 | 26.7 | p<0.001
Communication with Provider Rating^d^ | 37.6 | 38.5 | p=0.003

a STAI=Spielberger State-Trait Anxiety Inventory, range of scores 6 to 24;

b range 9–45;

c range 6–30;

d range 6–42;

e range 0–12

In the US study, participants were asked to view and rate slide images of clinic waiting rooms.71 The slides were from 28 waiting rooms and included clinics in renovated houses, in office buildings, and connected to hospitals. The rooms varied in size, color, lighting, and furnishings. A factor analysis found that perceived quality of care was higher for waiting rooms rated high on “attractive lighting” and “colorful and neat” and lower for waiting rooms rated as “unusual-looking.” There were differences between the college student and the senior citizen groups and a significant gender by number of office visits interaction. The factor analysis for comfort in the environment found that people were more comfortable in waiting rooms described as “tasteful” or “decorative” and less comfortable in waiting rooms described as “dark and sparse” or “strange and uncomfortable.” There were differences between the college students and senior citizens and between men and women. Although clinic waiting rooms are not, by strict definition, provider working areas, we have included this study as it presents patient perceptions of the overall clinic environment.

A systematic review of seven studies assessing patient satisfaction with the use of EHRs in the exam room during visits with providers found mixed results.72 The authors noted methodological problems with the studies. Pooled results from 3 studies indicated higher patient satisfaction following the introduction of EHRs in the exam rooms (mean difference of 3.7%). One of the studies included in the review was done in a VA primary care clinic. That study found that patients seeing residents were more likely to report a negative effect of the EHR on the patient-physician interaction but that only 8% of patients thought that the computer interfered with their relationship with their physician.

#### Summary of Findings for Physical Environment

The available evidence suggests that physical environment can affect patients’ anxiety levels before and after their appointments, satisfaction with doctor-patient communications, and perceived quality of care. However, additional research is needed to determine the specific elements of the environment that influence these outcomes and whether environment may also have an effect on additional outcomes such as patient safety and quality of care.

#### Quality and Strength of Evidence for Physical Environment

The percentage of studies meeting quality criteria for non-randomized trials is shown in Figure 8. With only one study reporting actual patient satisfaction there is insufficient evidence for this outcome.

Figure 8 Study Quality of Physical Environment Non-Randomized Studies

Notes: Only one study involved an intervention and the study did not meet the quality criteria for an intervention. The numbers on each bar indicate the number of studies that either met the study quality criteria (dark gray) or did not (light gray).

## KEY QUESTION #3 In studies that report provider outcomes, how are working conditions associated with provider outcomes (e.g., job satisfaction, productivity, pay)?

As noted in the background and conceptual model sections, we do not systematically review the evidence on the intermediate link between workplace conditions and provider outcomes. However, among the studies included in our review for evidence on the role of workplace condition on patient outcomes, three (two US and one European) also report findings on provider outcomes. We discuss those findings here, noting that these results are not necessarily representative of the evidence published to date on provider outcomes and workplace conditions in primary care settings. Linzer and colleagues6 found that greater workloads and less job autonomy resulted in greater physician ratings of stress and burnout and lower ratings of job satisfaction. They also found evidence that certain aspect of organizational culture (e.g. trust, quality emphasis, workplace cohesion) had similar affects on provider outcomes. The other US study of approximately 2,700 MDs from the 2007 American Medical Association file found that job satisfaction was not affected by the use of more advanced electronic medical records systems as compared to more basic systems.55 One study found that providers had higher levels of stress when working after a night “on call” compared to working after a night of not being on duty.52

In addition to the study by Linzer et al.6 reported above, two other organizational culture studies reported provider outcomes.64,67 In one study, physicians and physician assistants at PCMH clinics reported significantly lower emotional exhaustion.64 In the second study, physicians reported that office atmosphere, quality of life at work, and workload all improved when psychologists were integrated into family practice.67

One study of physical environment also reported limited provider outcome data.70 Staff members expressed significantly greater work satisfaction in a new facility but there were no differences in psychological symptoms. They felt the new work environment was more professional and allowed them to provide improved service to patients