# REFERENCES

1 Institute of Medicine. To Err is Human: Building a Safer Health System. Washington, D.C. National Academy Press. 2000.
2 Wachter RM. The end of the beginning: patient safety five years after ‘To Err Is Human’. Health Affairs. 2004;23:534-545.
3 Wachter RM. Patient safety at ten: unmistakable progress, troubling gaps. Health Affairs. 2010;29(1):165-173. [pmid: 19952010].
4 Hickam DH, Severance S, Feldstein A, et al. The effect of health care working conditions on patient safety. Evidence Report/Technology Assessment Number 74. (Prepared by Oregon Health & Science University under Contract No 290-97-0018). Rockville, MD. Agency for Healthcare Research and Quality. 2003.
5 Baron RJ, Fabens EL, Schiffman M, Wolf E. Electronic health records: just around the corner? or over the cliff?. Ann Intern Med. 2005;143:222-6. [pmid: 16061920].
6 Linzer M, Manwell LB, Williams ES, et al. Working conditions in primary care: physician reactions and care quality. Ann Intern Med. 2009;151(1):28-36. [pmid: 19581644].
7 Hauer KE, Durning SJ, Kernan WN, et al. Factors associated with medical students’ career choices regarding internal medicine. JAMA. 2008;300(10):1154-64. [pmid: 18780844].
8 Bodenheimer T, Grumbach K, Berenson RA. A lifeline for primary care. N Engl J Med. 2009;360:2693-6. [pmid: 19553643].
9 Wallace JE, Lemaire JB, Ghali WA. Physician wellness: a missing quality indicator. Lancet. 2009;374:1714-21. [pmid: 19914516].
10 Stone PW, Harrison MI, Feldman P, et al. Organizational climate of staff working conditions and safety-an integrative model. Henriksen K, Battles JB, Marks ES, Lewin DI, editors. Advances in Patient Safety: From Research to Implementation (Vol 2: Concepts and Methodology). Rockville, MD. Agency for Healthcare Research and Quality. 2005.
11 Warren N, Hodgson M, Craig T, Dyrenforth S, Perlin J, Murphy F. Employee working conditions and healthcare system performance: the Veterans Health Administration experience. J Occup Environ Med. 2007;49:417-429. [pmid: 17426525].
12 Donabedian A. Evaluating the quality of medical care. Milbank Mem Fund Q. 1966;44:166-206. [pmid: 5338568].
13 Mitchell PH, Lang NM. Framing the problem of measuring and improving healthcare quality: has the quality health outcomes model been useful?. Med Care. 2004;42:II4-11. [pmid: 14734937].
14 Campbell SM, Roland MO, Buetow SA. Defining quality of care. Soc Sci Med. 2000;51:1611-25. [pmid: 11072882].
15 Elder N, Dovey SM. Classification of medical errors and preventable adverse events in primary care: A synthesis of the literature. J Fam Pract. 2003;51:927-32. [pmid: 12485545].
16 Sitzia J, Wood N. Patient satisfaction: a review of issues and concepts. Soc Sci Med. 1997;45(12):1829-43. [pmid: 9447632].
17 Parker PA, Kulik JA. Burnout, self- and supervisor-rated job performance, and absenteeism among nurses. J Behav Med. 1995;18(6):581-599. [pmid: 8749987].
18 Shader K, Broome ME, Broome CD, West ME, Nash M. Factors influencing satisfaction and anticipated turnover for nurses in an academic medical center. J Nurs Admin. 2001;31(4):210-216.
19 Williams ES, Skinner AC. Outcomes of physician job satisfaction: A narrative review, implications, and directions for future research. Health Care Manage Rev. 2003;28(2):119-40. [pmid: 12744449].
20 Williams ES, Manwell LB, Konrad TR, Linzer M. The relationship of organizational culture, stress, satisfaction, and burnout with physician-reported error and suboptimal patient care: results from the MEMO study. Health Care Manage Rev. 2007;32(3):203-12. [pmid: 17666991].
21 Devoe J, Fryer GE, Hargraves JL, Phillips RL, Green LA. Does career dissatisfaction affect the ability of family physicians to deliver high-quality patient care?. J Fam Pract. 2002;51(3):223-8. [pmid: 11978232].
22 Haas LJ, Glazer K, Houchins J, Terry S. Improving the effectiveness of the medical visit: a brief visit-structuring workshop changes patients’ perceptions of primary care visits. Patient Educ Couns. 2006;62(3):374-8. [pmid: 16870386].
23 McKevitt C, Morgan M, Dundas R, Holland WW. Sickness absence and ‘working through’ illness: a comparison of two professional groups. J Public Health Med. 1997;19:295-300. [pmid: 9347453].
24 Jones JW, Barge BN, Steffy BD, Fay LM, Kunz LK, Wuebker LJ. Stress and medical malpractice: organizational risk assessment and intervention. J Appl Psychol. 1988;73:727-35. [pmid: 3209582].
25 Shanafelt TD, Bradley KA, Wipf JW, Back AL. Burnout and self reported patient care in an internal medicine residency program. Ann Intern Med. 2002;136:358-67. [pmid: 11874308].
26 Fahrenkopf AM, Sectish TC, Barger LK, et al. Rates of medication errors among depressed and burnt out residents: prospective cohort study. BMJ. 2008;336:488-91. [pmid: 18258931].
27 Misra-Hebert AD, Kay R, Stoller JK. A review of physician turnover: rates, causes, and consequences. Am J Med Qual. 2004;19:56-66. [pmid: 15115276].
28 West CP, Huschka MM, Novotny PJ, et al. Association of perceived medical errors with resident distress and empathy: a prospective longitudinal study. JAMA. 2006;296:1071-78. [pmid: 16954486].
29 Sirriyeh R, Lawton R, Gardner P, Armitage G. Coping with medical error: a systematic review of papers to assess the effects of involvement in medical errors on healthcare professionals’ psychological well-being. Qual Saf Health Care. 2010;19:e43. [pmid: 20513788].
30 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.0.2 [updated September 2009]. The Cochrane Collaboration. 2009. Available at www.cochrane-handbook.org. Accessed August 29, 2011.
31 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63:513-23. [pmid: 19595577].
32 Caldow J, Bond C, Ryan M, et al. Treatment of minor illness in primary care: a national survey of patient satisfaction, attitudes and preferences regarding a wider nursing role. Health Expect. 2007;10(1):30-45. [pmid: 17324193].
33 Dierick-van Daele AT, Metsemakers JF, Derckx EW, Spreeuwenberg C, Vrijhoef HJ. Nurse practitioners substituting for general practitioners: randomized controlled trial. J Adv Nurs. 2009;65(2):391-401. [pmid: 19191937].
34 Laurant MG, Hermens RP, Braspenning JC, Akkermans RP, Sibbald B, Grol RP. An overview of patients’ preference for, and satisfaction with, care provided by general practitioners and nurse practitioners. J Clin Nurs. 2008;17(20):2690-8. [pmid: 18647199].
35 Mundinger MO, Kane RL, Lenz ER, et al. Primary care outcomes in patients treated by nurse practitioners or physicians: a randomized trial. JAMA. 2000;283(1):59-68. [pmid: 10632281].
36 Roblin DW, Becker ER, Adams EK, Howard DH, Roberts MH. Patient satisfaction with primary care: does type of practitioner matter?. Med Care. 2004;42(6):579-90. [pmid: 15167326].
37 Castro A, Ruiz E. The effects of nurse practitioner cultural competence on Latina patient satisfaction. J Am Acad Nurse Pract. 2009;21(5):278-86. [pmid: 19432912].
38 Edwards A, Elwyn G, Hood K, et al. Patient-based outcome results from a cluster randomized trial of shared decision making skill development and use of risk communication aids in general practice. Fam Pract. 2004;21(4):347-54. [pmid: 15249521].
39 Goulet F, Gagnon R, Gingras M-E. Influence of remedial professional development programs for poorly performing physicians. J Contin Educ Health Prof. 2007;27(1):42-8. [pmid: 17385737].
40 Haas JS, Cook EF, Puopolo AL, Burstin HR, Cleary PD, Brennan TA. Is the professional satisfaction of general internists associated with patient satisfaction?. J Gen Intern Med. 2000;15(2):122-8. [pmid: 10672116].
41 Zabar S, Hanley K, Stevens DL, et al. Can interactive skills-based seminars with standardized patients enhance clinicians’ prevention skills? Measuring the impact of a CME program. Patient Educ Couns. 2010;80(2):248-52. [pmid: 20053518].
42 Campbell JL, Ramsay J, Green J. Practice size: impact on consultation length, workload, and patient assessment of care. Br J Gen Pract. 2001;51(469):644-50. [pmid: 11510394].
43 Campbell JL, Ramsay J, Green J, Harvey K. Forty-eight hour access to primary care: practice factors predicting patients’ perceptions. Fam Pract. 2005;22(3):266-8. [pmid: 15778237].
44 Carlsen B, Aakvik A. Patient involvement in clinical decision making: the effect of GP attitude on patient satisfaction. Health Expect. 2006;9(2):148-57. [pmid: 16677194].
45 Dong L, Van H, Wang D. Polypharmacy and its correlates in village health clinics across 10 provinces of Westem China. J Epidemiol Community Health. 2010;64(6):549-53. [pmid: 19854749].
46 Grytten J, Carlsen F, Skau I. Services production and patient satisfaction in primary care. Health Policy. 2009;89(3):312-21. [pmid: 18656276].
47 Luras H. The association between patient shortage and patient satisfaction with general practitioners. Scand J Prim Health Care. 2007;25(3):133-9. [pmid: 17846930].
48 Magan P, Alberquilla A, Otero A, Ribera 1M. Hospitalizations for ambulatory care sensitive conditions and quality of primary care: their relation with socioeconomic and health care variables in the Madrid regional health service (Spain). Med Care. 2011;49(1):17-23. [pmid: 20978453].
49 Nyweide DJ, Weeks WB, Gottlieb DJ, Casalino LP, Fisher ES. Relationship of primary care physicians’ patient caseload with measurement of quality and cost performance. JAMA. 2009;302(22):2444-50. [pmid: 19996399].
50 Salisbury C, Wallace M, Montgomery AA. Patients’ experience and satisfaction in primary care: secondary analysis using multilevel modelling. BMJ. 2010;341:c5004. [pmid: 20940212].
51 Fairchild DG, McLoughlin KS, Gharib S, et al. Productivity, quality, and patient satisfaction: comparison of part-time and full-time primary care physicians. J Gen Intern Med. 2001;16(10):663-7. [pmid: 11679033].
52 French DP, McKinley RK, Hastings A. GP stress and patient dissatisfaction with nights on call: an exploratory study. GP stress and patient satisfaction. Scand J Prim Health Care. 2001;19(3):170-3. [pmid: 11697558].
53 Parkerton PH, Wagner EH, Smith DG, Straley HL. Effect of part-time practice on patient outcomes. J Gen Intern Med. 2003;18(9):717-24. [pmid: 12950480].
54 McKinstry B, Walker J, Porter M, et al. The impact of general practitioner morale on patient satisfaction with care: a cross-sectional study. BMC Fam Pract. 2007;8:57. [pmid: 17903255].
55 DesRoches CM, Campbell EG, Rao SR, et al. Electronic health records in ambulatory care--a national survey of physicians. N Engl J Med. 2008;359(1):50-60. [pmid: 18565855].
56 Feldstein AC, Perrin NA, Unitan R, et al. Effect of a patient panel-support tool on care delivery. Am J Manag Care. 2010;16(10):e256-66. [pmid: 20964477].
57 Weiner M, El Hoyek G, Wang L, et al. A web-based generalist-specialist system to improve scheduling of outpatient specialty consultations in an academic center. J Gen Intern Med. 2009;24(6):710-5. [pmid: 19367375].
58 Budzi D, Lurie S, Singh K, Hooker R. Veterans’ perceptions of care by nurse practitioners, physician assistants, and physicians: a comparison from satisfaction surveys. J Am Acad Nurse Pract. 2010;22(3):170-6. [pmid: 20236402].
59 Shapiro MJ, Morrey J, Small SD, et al. Simulation based teamwork training for emergency department staff: does it improve clinical team performance when added to an existing didactic teamwork curriculum?. Qual Saf Health Care. 2004;13(6):417-21. [pmid: 15576702].
60 Christianson JB, Leatherman S, Sutherland K. Lessons from evaluations of purchaser pay-for-performance programs. Med Care Res Rev. 2008;65(6 Suppl):5S-35S. [pmid: 19015377].
61 Van Herck P, De Smedt D, Annemans L, Remmen R, Rosenthal M, Sermeus W. Systematic review: Effects, design choices, and context of pay-for-performance in health care. BMC Health Serv Res. 2010;10(1):247. [pmid: 20731816].
62 Bean-Mayberry BA, Chang CC, McNeil MA, Whittle J, Hayes PM, Scholle SH. Patient satisfaction in women’s clinics versus traditional primary care clinics in the Veterans Administration. J Gen Intern Med. 2003;18(3):175-81. [pmid: 12648248].
63 Gilfillan RJ, Tomcavage J, Rosenthal MB, et al. Value and the medical home: effects of transformed primary care. Am J Manag Care. 2010;16(8):607-14. [pmid: 20712394].
64 Reid RJ, Fishman PA, Yu O, et al. Patient-centered medical home demonstration: a prospective, quasi-experimental, before and after evaluation. Am J Manag Care. 2009;15(9):e71-87. [pmid: 19728768].
65 Adam P, Brandenburg DL, Bremer KL, Nordstrom DL. Effects of team care of frequent attenders on patients and physicians. Fam Syst Health. 2010;28(3):247-57. [pmid: 20939629].
66 Boyd CM, Reider L, Frey K, et al. The effects of guided care on the perceived quality of health care for multi-morbid older persons: 18-month outcomes from a cluster randomized controlled trial. J Gen Intern Med. 2010;25(3):235-42. [pmid: 20033622].
67 Chomienne M-H, Grenier J, Gaboury I, Hogg W, Ritchie P, Farmanova-Haynes E. Family doctors and psychologists working together: doctors’ and patients’ perspectives. J Eval Clin Pract. 2011;17(2):282-7. [pmid: 20874836].
68 Hogg W, Lemelin J, Dahrouge S, et al. Randomized controlled trial of anticipatory and preventive multidisciplinary team care: for complex patients in a community-based primary care setting. Can Fam Physician. 2009;55(12):e76-85. [pmid: 20008582].
69 Sellors J, Kaczorowski J, Sellors C, et al. A randomized controlled trial of a pharmacist consultation program for family physicians and their elderly patients. CMAJ. 2003;169(1):17-22. [pmid: 12847034].
70 Rice G, Ingram J, Mizan J. Enhancing a primary care environment: a case study of effects on patients and staff in a single general practice. Br J Gen Pract. 2008;58(552):465-70. [pmid: 18611307].
71 Arneill AB, Devlin AS. Perceived quality of care: the influence of the waiting room environment. J Environ Psychol. 2002;22(4):345-60.
72 Irani JS, Middleton JL, Marfatia R, Omana ET, D’Amico F. The use of electronic health records in the exam room and patient satisfaction: a systematic review. J Am Board Fam Med. 2009;22:553-62. [pmid: 19734402].
73 Parmelli E, Flodgren G, Schaafsma ME, Baillie N, Beyer FR, Eccles MP. The effectiveness of strategies to change organizational culture to improve healthcare performance. Cochrane Database Syst Rev. 2011;(1). Art. No.: CD008315.
74 Gulwadi GB, Joseph A, Keller AB. Exploring the impact of the physical environment on patient outcomes in ambulatory care settings. HERD. 2009;2(2):21-41. [pmid: 21161928].
75 Ichniowki C, Shaw K, Prennushi G. The effects of human resource management practices on productivity: working paper. New York. Columbia University. 1994.
76 Huselid MA. The impact of human resource management practices on turnover, productivity, and corporate financial performance. Acad Manage J. 1995;38(3):635-72.
77 MacDuffie JP. Human resourcetion systems in the world auto industry. Indus Lab Rel Rev. 1995;48:197-221.