# METHODS

## TOPIC DEVELOPMENT

This project was nominated by Michael Hodgson, MD, MPH. The primary aim was to review the evidence on the associations between primary care workplace conditions and patient outcomes as depicted in Figure 2. The key questions and scope of the report were refined with input from a technical expert panel.

Figure 2 Analytic Framework

^*^ Working Conditions of Ambulatory Primary Care Clinics

1. Human resources practices (work volume, scheduling, training/skills required, task design, information systems)
2. Organizational culture (organizational climate, professional culture, hierarchy)
3. Physical environment (safety, lighting/temperature, physical layout)

The final key questions are:

Key Question #1 How are HR practices, such as skill levels, training, workload, hours worked, autonomy, and electronic medical records/systems, associated with patient outcomes?
  a. quality of care (access and effectiveness)
  b. safety (medication errors)
  c. patient satisfaction (with provider, with clinic/practice)
Key Question #2 How are other working conditions, such as organizational culture or physical environment, associated with patient outcomes?
  a. quality of care (access and effectiveness)
  b. safety (medication errors)
  c. patient satisfaction (with provider, with clinic/practice)
Key Question #3 In studies that report provider outcomes, how are HR practices and working conditions associated with provider outcomes (e.g., job satisfaction, productivity, pay)?

## SEARCH STRATEGY

We conducted searches for human resource practices [separate searches for staffing and workflow], organizational culture, and physical environment in MEDLINE and PsycINFO. We developed our search strategies based on the 2003 AHRQ report.4 To insure that we captured studies of team-based approaches to care (as requested by our TEP), we also did focused searches in both MEDLINE and PsycINFO. MEDLINE search strategies are presented in Appendix A. We included randomized controlled trials, systematic reviews, and prospective studies published in English from 2000 to September 2011. Our search focused on primary care physicians, nurse practitioners, and physician assistants as providers and adult patients receiving care in ambulatory, primary care settings. For provider outcomes, we searched MEDLINE and the Cochrane Effective Practice and Organization of Care (EPOC) Group Web site for recent systematic reviews or meta-analyses. Additional citations were identified from reference lists of related articles.

## STUDY SELECTION

Titles and abstracts were reviewed by researchers trained in the critical analysis of literature. Full text versions of potentially eligible articles were retrieved for review. Our inclusion criteria were:

1. Study published in English language
2. Randomized trial, observational study or systematic review (the article had to present data analysis results)
3. Outpatient, adult, primary care setting, without focus on one specific disease or patient population
4. Study addressed working conditions for primary care physician, nurse practitioner, or physician assistant
5. Reported outcomes of interest:
  - Patient Outcomes – quality of care, patient safety, patient satisfaction
  - Provider Outcomes – job satisfaction, productivity, pay

## DATA ABSTRACTION

We abstracted the following data for each included study for Key Questions #1 and #2: author, date of publication, country where study was conducted, funding source, characteristics of included patients, providers and/or clinics, study design, working conditions evaluated, and patient outcomes (quality [access, effectiveness], safety [ medication errors], and satisfaction [with provider, with practice or care]). We also abstracted data on provider outcomes, where provided. Additional data for Key Question #3 was obtained from recent systematic reviews or meta-analyses. All abstraction was done by trained research personnel under the supervision of the Principal Investigator.

## QUALITY ASSESSMENT

We assessed study quality of randomized trials according to the following criteria: 1) adequate allocation concealment, 2) blinding of key study personnel, 3) analysis by intention-to-treat, and 4) reporting of number of withdrawals/dropouts by group assignment.30 Studies were rated as good, fair, or poor quality. A rating of good generally indicated that the trial reported adequate allocation concealment, appropriate blinding, analysis by intent-to-treat, and reasons for dropouts/attrition. Studies were generally rated poor if the method of allocation concealment was inadequate or not defined, blinding was not defined, analysis by intent-to-treat was not utilized, and reasons for dropouts/attrition were not reported and/or there was a high rate of attrition. For non-randomized trials, we determined risk of bias based on critical elements related to the population, intervention, outcomes, measurement, and confounding (Appendix B).

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies, organized by working condition. We critically analyzed studies to compare their characteristics, methods, and findings. Due to heterogeneity of interventions and outcomes assessed we were unable to pool results from different studies. We compiled a summary of findings for each working condition, and drew conclusions based on qualitative synthesis of the findings.

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence using the method reported by Owens et al.31 Briefly, for each outcome evaluated, the strength of the evidence was assessed based on: 1) risk of bias; 2) consistency; 3) directness; and 4) precision. Based on these four domains, the overall evidence was rated as: 1) high, meaning high confidence that the evidence reflects the true effect; 2) moderate, indicating moderate confidence that further research may change our confidence in the estimate of effect and may change the estimate; 3) low, meaning there is low confidence that the evidence reflects the true effect; and 4) insufficient, indicating that evidence either is unavailable or does not permit a conclusion.

## PEER REVIEW

A draft version of this report was reviewed by members of our technical expert panel as well as VA clinical leadership. Their comments and our responses are presented in Appendix C.