# INTRODUCTION

A patient safety movement that began with a 1999 Institute of Medicine report on the prevalence of preventable medical errors has spawned both policy to change health care systems and a growing body of literature aimed at understanding the causes of such errors.1–3 A 2003 AHRQ systematic review investigated the role that workplace conditions play in explaining patient safety and found that workloads, work schedules, lengths of work shifts, and stress levels affected rates of non-fatal adverse outcomes, mortality rates, medication errors, and other patient safety measures.4 However, much of this evidence relies on studies based in hospitals and focuses on nurse and resident staffing or is based on studies in non-healthcare settings.

## BACKGROUND

A large body of evidence has shown clear linkages between workplace conditions and employee satisfaction and stress in a wide variety of organizational and industry settings.5 In the healthcare industry, increasing interest in understanding these linkages has stemmed from the idea that healthcare providers’ working environments also affect important patient outcomes, including safety, quality of care and satisfaction.6 Additionally, meeting objectives of the current healthcare reform to increase healthcare quality by increasing the availability of primary care providers and making care safer, more efficient, effective and patient-centered hinges on the ability to deal with the documented shortage of primary care providers in the US7,8 and at the same time improve patient outcomes.

The purpose of this report is to systematically review the evidence on the role of primary care providers’ workplace conditions in influencing patient outcomes. The focus on primary care providers’ work environment will provide evidence on increasing healthcare quality. While the focus of this review is on patient outcomes, we do discuss implications for providers and recent review studies that highlight the importance of provider wellness as a component of high quality care.9 Results from this review may inform policymakers as they endeavor to implement aspects of the healthcare reform related to increasing the supply of primary care providers and improving patient outcomes.

Following the 2003 AHRQ report,4 we focused on the following workplace conditions: 1) human resource practices 2) organizational culture, and 3) physical environment, but restricted our review to studies on primary care providers (physicians, physician assistants, and nurse practitioners) in ambulatory care settings. Note that the workplace condition constructs, specifically “human resources practices” and “organizational culture”, may overlap. However, our categorization of these workplace conditions does not affect the evidence presented; it merely serves as a way to organize a long list of workplace conditions. As mentioned above, we restricted our analysis to studies focused on the following patient outcomes, broadly defined: patient care quality, medical errors, patient safety, and patient satisfaction. We conceptualized primary or ambulatory care to include clinics and providers that serve as a first point of contact for patients where common illnesses and conditions are treated. Therefore, we excluded studies that focused on one specific disease, even chronic conditions that may be managed by a primary care provider, or one specific patient population (e.g. diabetics). We discuss these work environment concepts, patient safety measures, and our conceptual model below.

## WORKING CONDITIONS

Our key questions, study protocol and populations, interventions, settings and outcomes of interest were guided by consultation with a panel of experts.

We delineated workplace conditions of primary care providers into three categories: human resources practices, organizational culture and physical environment. Note that some elements of “human resources practices” could conceivably be classified as characteristics of a workplace’s organizational culture (and vice versa), but we have roughly followed the categorizations from the 2003 AHRQ report.4 In another AHRQ report,10 the authors describe elements of organizational climate as part of the healthcare structures, whereas the actual workplace practices are part of the processes (see also our conceptual model below). These workplace condition classifications are simply geared at organizing the presentation of results and do not change or in any way shape the evidence presented. Note that many of these constructs are measured in varied ways across studies. We mention some of the most commonly used measures below and provide details on the measures used in each study in Appendix D, Tables 1–3, 7, and 12.

### Human Resources Practices

Human resources practices encompass all organizational practices and policies that pertain to managing employees. In this study, we focused on skill levels/training and work systems. Skill levels and training reflect some measure of knowledge, either through formal general training (i.e., physician vs. nurse practitioner) or more specific training aimed at increasing providers’ knowledge or skills in helping patients. Note that we did not include studies that investigated the effect of disease specific training on patient outcomes. Work systems include workload, scheduling, autonomy, and other systems or structures in place that affect how providers do their jobs, such as electronic medical records or computerized systems. Workload is typically measured as the “listsize” (number of patients a physician has), by the number of procedures performed, the number of patients seen, and time pressures related to work pace. A related concept is provider scheduling, which may be measured as shift length, typical hours, or days of the week worked. Scheduling is studied less in the ambulatory care setting than in the hospital setting. Autonomy or control of one’s work refers to the flexibility that providers have in exactly how they get their tasks completed.

While pay systems, and in particular pay for performance settings, are an important component of workplace conditions and human resource practices that likely influence patient (and provider) outcomes, we do not systematically review this literature in this report. There is a large existing literature on pay for performance spanning several disciplines, in general, but also a large growing literature on this topic in healthcare settings. We discuss recent systematic reviews on this topic below.

### Organizational Culture

Organizational culture pertains to issues related to the social norms in a workplace. We focused on studies that investigated organizational climate, professional culture, and the structural organization or hierarchies present in a workplace, including the use of teams. Organizational climate includes provider perceptions of how open the organization is to change, what is valued at the organization (e.g. patient safety, learning), and expectations about how to work and fit in at the organization. For example, one VA study identified the following factors of climate: employee focus, support (group processes and supervision), and professional demands.11 Professional culture involves how value perceptions vary across different professions within the organization and how teamwork and relationships within the organization are valued. Finally, in this study, organizational culture encompasses organizational structures or hierarchies related to the division of labor within an organization. We include “team-based care” as a component of organizational culture as it is often accompanied with other cultural or structural characteristics that facilitate teamwork. The literature on healthcare teams (and related concepts such as patient centered care) is large, but for this review, we focused on studies that investigated the effectiveness of teams where at least one team member is a physician, nurse practitioner, or physician assistant.

### Physical Environment

Physical environment pertains to issues related to the direct physical characteristics of the workplace. We focused on studies that investigate environmental safety, lighting, temperature, and physical layout of clinics. Environmental safety includes air quality, indoor pollution, toxic exposures, and noise. The physical environment also includes aesthetic and comfort aspects of the workplace, such as lighting, temperature, and humidity. Finally, the physical layout at the workplace, such as whether there are obstacles or large distances between work stations, may influence patient outcomes.

## CONCEPTUAL MODEL

We draw from several quality of care models from the nurse staffing literature that build on Donabedian’s work delineating quality as it relates to healthcare structures, processes, and outcomes.12 In Figure 1, we outline the main model noting that these relationships can also be outlined at different levels, including individual, group, organizational or system. We also note that this model can easily be expanded with the complexity added due to interactions at various levels and the possibility of bidirectional effects (of say, structures and processes).13 Additionally, we have included intermediary outcomes in this model; in particular, we highlight that an underlying behavioral mechanism exists whereby the organizational structures and processes affect provider’s job satisfaction, productivity, pay, and similar outcomes. Studies that focused solely on these intermediary outcomes are beyond the scope of this report. For the purposes of this report, we focused on the general effect of workplace conditions and related clinical processes on patient outcomes.

Figure 1 Conceptual Model – Quality of Care in Primary Care

## PATIENT OUTCOMES

We focused on the following patient outcomes: quality of care, patient safety, and patient satisfaction.

### Quality of Care

Quality of care is typically categorized broadly into a)access to care and b)effectiveness of care.14 Accessibility addresses whether patients can actually get the care they need while clinical effectiveness addresses whether the care received results in the intended outcome. Both constructs are influenced by structures and processes in the healthcare setting. For example, access can be limited by both physical location (structure) and affordability (process). Effectiveness includes knowledge or evidence-based care, guideline concordant care, or clinical effectiveness and is often measured as provider compliance to the guidelines or evidence.

### Patient Safety

Patient safety can be broadly related to diagnosis errors, treatment errors, and perhaps missing preventive services.15 However, because there is some overlap in treatment and diagnostic errors with quality of care, we included performance metrics dealing with missing preventive services or other metrics that represent management of disease or appropriate care with the quality measure in this report even though failure to manage chronic conditions or ensure preventive care utilization can clearly lead to adverse events. Thus, we refer to patient safety as medication errors in the remainder of the report. Similar to quality, medication errors may be the result of structures within the health care system or clinical and non-clinical processes.

### Patient Satisfaction

Patient satisfaction often includes components of quality of care and patient safety as patients tend to be more satisfied if they feel they are receiving high quality care and they are not subject to medical errors.16 Broadly, we classify patient satisfaction as satisfaction with the provider and satisfaction with the clinic. Satisfaction can be measured using different scales and may be influenced as much by clinical care processes as by structures or the clinic environment (i.e., receptionist, waiting time, etc.).

## PROVIDER OUTCOMES

As noted, the aim of this report was to focus on patient outcomes. However, as outlined in the conceptual model (Figure 1), the underlying mechanism of the effect of workplace conditions on patient outcomes is likely through the effect of workplace conditions on providers. Although we did not systematically review studies focused on providers, we briefly discuss the general findings from this literature.

Following a recent review, we refer to provider outcomes in this context as aspects of provider “wellness,” which include physical, mental/psychological, and emotional health.9 Understanding the effects of workplace conditions on provider wellness is likely complicated by the interdependent nature the individual provider characteristics, workplace conditions, and larger healthcare system factors.

One of the most frequently studied provider outcomes is psychological stress, which correlates with poor physical and mental health. Various healthcare workplace conditions have been linked to increased stress levels and negative physical health for providers, including workload, pay, organizational structure (bureaucratic), restricted autonomy, and a professional culture that does not encourage providers to seek medical help for themselves.9

Beyond the immediate physical and mental health effects of workplace conditions on providers are the effects that ripple through the healthcare system. The effects of job stress on healthcare providers’ absenteeism, burnout, performance, and intention to quit or leave,17–20 have been well documented in the literature. Not surprisingly, stressed employees are more likely to be absent from work, be low performers, and have greater turnover rates than other employees. Similarly, satisfied providers are more likely to have satisfied patients. 21,22 At the organizational level, these effects can permeate the organizational culture to create an unhealthy and ineffective workforce.20,23 Furthermore, stressed and dissatisfied healthcare providers are more likely to make medical mistakes that effect patients24–26 and have dissatisfied patients.27

As noted above, these relationships are complex and dynamic in such a way that not only are the effects felt at many levels (provider, patient, healthcare system), but also they create a cycle of reinforcing behaviors and outcomes. For example, a heavy workload may cause a provider excessive psychological stress, which may in turn influence her physical health and also cause her to be more prone to medical errors, which may create even more distress repeating the cycle.28,29

As outlined in the Wallace et al. review,9 there are several potential policy interventions at various levels that might positively influence provider wellbeing. In this study, we focused on studies that shed light on possible workplace interventions (as opposed to provider self-care or higher-order system level interventions) that will ultimately impact patient outcomes. Such changes to workplace conditions will likely also influence provider outcomes. While examples of workplace changes that positively affect both providers and patients exist, such as an organizational culture that emphasizes quality, reduces provider stress and increases quality of care for patients,6 we point out that there are some workplace changes that may yield greater patient outcomes at the expense of poorer provider outcomes, such as electronic medical records.