# EVIDENCE TABLES

Appendix D, Table 1 Description of Human Resources Practices Studies – United States

Appendix D, Table 2 Description of Human Resources Practices Studies – Europe

Appendix D, Table 3 Description of Human Resources Practices Studies – Outside of US or Europe

Appendix D, Table 4 Quality of Care Outcomes - Human Resources Practices Studies

Appendix D, Table 5 Patient Safety Outcomes – Human Resources Practices Studies

Appendix D, Table 6 Patient Satisfaction Outcomes – Human Resources Practices Studies

Appendix D, Table 7 Description of Organizational Culture Studies

Appendix D, Table 8 Quality of Care Outcomes – Organizational Culture Studies

Appendix D, Table 9 Patient Safety Outcomes – Organizational Culture Studies

Appendix D, Table 10 Patient Satisfaction Outcomes – Organizational Culture Studies

Appendix D, Table 11 Provider Outcomes – Organizational Culture Studies

Appendix D, Table 12 Description of Physical Environment Studies