# PEER REVIEW COMMENTS/AUTHOR RESPONSES

REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
Yes | No response needed
Yes, articulate and concise | No response needed
Yes | No response needed
Yes | No response needed
Yes. Well designed and conceptualized with appropriate questions to guide the review. Excellent use of criteria for literature search and review of the literature. | Thank you.
The rationale for choosing these 3 areas specifically: HR, organizational culture, and physical environment probably warrants some enhancement. Further, the definitions and limits of each of these categories seems somewhat arbitrary. For example, would sufficient staffing to ensure a appropriate roles/functions for team based care be considered HR or organizational culture? Regarding outcomes, you use the term patient safety, but it is often unclear that you really mean to include all quality metrics including typical clinical outcomes such as admissions and ED utilization. What about performance metrics such as chronic disease outcomes such as glycemic control etc?? I am still not sure if you included these as well. | We acknowledge that these categorizations are arbitrary, but we do not think that how we’ve organized this (by the categorizations that we’ve used) undermines our presentation of the evidence, which in most cases is lacking. Our main rationale for using these categorizations is that we wanted to build on the previous similar AHRQ report, but because of the substantial overlap collapsed a few of the categories. Nonetheless, we’ve inserted a disclaimer about this categorization. Regarding patient safety, this is a valid point. We agree that there may be some overlap with patient safety and effectiveness (which we point out in the report), where the latter would include “performance metrics such as chronic disease outcomes such as glycemic control etc.” We have added some discussion to clarify this.
2. Is there any indication of bias in our synthesis of the evidence?
No | No response needed
No | No response needed
No | No response needed
No | No response needed
No Good description of algorithm for choosing studies. Excellent use of criteria for quality of review and for systematic reporting of findings. | Thank you.
No | No response needed
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
No | No response needed
It appears that a thorough literature review was conducted; however I have not done my own lit search on this topic to know if there are additional references | No response needed
Here are a few suggestions:; 1. Williams ES, Konrad TR, Linzer M, et al. Physician, Practice, and Patient Characteristics Related to Primary Care Physician Physical and Mental Health: Results from the Physician Worklife Survey. Health Serv Res 2002;37(1):121–143.; 2. Clarke SP, Rockett JL, Sloane DM, et al. Organizational climate, staffing, and safety equipment as predictors of needlestick injuries and near-misses in hospital nurses. Am J Infection Control 2002;30(4):207–216; 3. Aiken L, Clarke S, Sloane D, et al. Hospital nurse staffing and patient mortality, nurse burnout, and job dissatisfaction. JAMA 2002;288:1987–1993.; 4. Needleman J, Buerhaus P, Mattke S, et al. Nurse-staffing levels and the quality of care in hospitals. NE Journal of Medicine 2002;346(22):1715–1722.; 5. Stone PW, Harrison ML, Feldman P, et al. Organizational Climate of Staff Working Conditions and Safety—An Integrative Model. Advances in Patient Safety: From Re-search to Implementation. Volumes 1–4, AHRQ Publication Nos. 050021 (1–4). February 2005. Agency for Healthcare Research and Quality, Rockville, MD. http://www.ahrq.gov/qual/advances/ Volume 2, Concepts & Methodology, pp 467–481; These basic references/syntheses do not appear in the citations, but the first is mentioned on page 10, just not referenced.; 1. Institute of Medicine. To Err is Human: Building a Safer Health System. Washington, DC: National Academy of Sciences; 2000.; 2. Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC: National Academy of Sciences; 2001.; 3. Institute of Medicine Committee on the Work Environment for Nurses and Patient Safety. Keeping Patients Safe: Transforming the Work Environment of Nurses. Ann Page, Editor. Washington DC: National Academy of Sciences; 2004. | Thank you for the additional suggested articles. We’ve pulled all of these references and discuss them here:; 1. Williams et al. – this article does not have any patient outcomes that we examine so it does not meet our inclusion criteria. However, the study does relate well to some of our discussion of provider outcomes, so we will make sure this paper is added/discussed in that section.; 2. Clarke et al. – this article does not meet our inclusion criteria because it is about needlesticks in hospital settings and deals with nurses’ workplace condition (while we focus on MDs, PAs, and NPs only).; 3. Aiken et al - this article does not meet our inclusion criteria because it deals with hospital settings and nurses’ workplace condition (while we focus on MDs, PAs, and NPs only in primary care settings).; 4. Needleman et al – same as #3.; 5. Stone et al – we will add this citation to our background/framework section.; We only cite the first Institute of Medicine report. We have changed the citation from Kohn et al. to Institute of Medicine.
No If there are other studies, I am not aware of them in the prescribed area of interest. There are studies looking at the effects of working conditions and workload of nurses. | No response needed
No Literature with data/results that I am familiar with has made it into this report. | No response needed
4. Additional suggestions or comments
While the report concludes that the evidence of an association of working conditions with health care outcomes is often lacking, alternative hypotheses are not explicitly entertained. It may be that health professionals are capable of “buffering” pateints from the effects of adverse working conditions, leading to null or mixed effects. | We have added this caveat.
None, excellent work | Thank you.
p. 5 – 5^th^ paragraph under Conclusions. The first sentence seems to indicate greater job satisfaction is associated with greater workloads and less control over work tasks. The sentence reads “…we found that greater workloads and less control over work tasks resulted in greater provider stress, burnout, and job satisfaction.” I would suggest some rewording if this is not the intent. Page 38 – Recommendations for Future Research. This section was weak in comparison to the rest of the report. The content is very general with little specific direction or suggestion of priority areas for future research. Given the focus on general healthcare reform and the budget constraints what we are facing in the VA, the authors may want to speculate on some specific areas or research questions that need addressing to help us prepare for tough times ahead. Are there specific practices or aspects of culture or of the physical environment that their findings would point to as logical next steps for research? Thank you for the opportunity to review this report. I appreciated the detail and the clarity of presentation. This type of work is important as we advance this area of knowledge. | Re pg. 5, 5^th^ paragraph: we’ve edited this. Re pg. 38: we’ve added some discussion.
It seems that there would be much overlap between HR, org culture, and physical environment. It is hard to know if some studies may have been overlooked because of the vagueness of these terms. This review will be helpful more to point out the limitations of the current literature, and the lack of clear relationship observed thus far between team staffing, training and function and specific outcomes. | This is a valid point, but we used fairly exhaustive lists of terms for all of these vague constructs, which may be unclear in the main part of the text (though can be seen in our appendices with search terms). We will add some discussion about this.
5. Please provide any recommendations on how this report can be revised to more directly address ocr assist implementation needs.
You might consider creating as appendices short checklists or worksheets, designed for use by hospital administrators, safety professionals, and worker teams to help them a) identify working conditions that can adversely impact both employee health and quality/safety of patient care and b) develop interventions to improve those conditions. This is a step beyond standard hazard evaluations, because it would flag conditions most strongly associated with patient outcomes. Many of these would be work organization domains that hazard evaluations do not normally address. These worksheets would help drive hospital interventions to address systems-level problems | We have forwarded your suggestion to the topic nominator..
This is valuable work as it relates to the healthcare personnel it represents in the clinic setting. Such work is also needed in the acute care settings. Given that the majority of the healthcare workforce is comprised of nurses in acute care settings, I would hope that a similar review would be conducted for acute care and include nurses as part of the population of interest. Studies related to nursing impact are being done but a systematic review has not been conducted and might be valuable as healthcare strives to become more effective with delivery of services and improvement in outcomes. | Thank you. Additional topics (such as acute care settings) can be nominated at the VA ESP Web site: http://www.hsrd.research.va.gov/publications/esp/
I can’t help but wonder if other important studies evaluating effect and impact of PCMH have been inadvertently excluded here because did not specifically include the three categories mentioned above. | The evidence group at the Minneapolis VA has reviewed the literature on PCMH for another VA program. To our knowledge there are no additional published reports of PCMH interventions.