# SEARCH STRATEGIES

## Staffing

Database: Ovid MEDLINE(R)

1. exp Medical Errors/
2. (medical errors or medication errors or diagnostic errors).mp.
3. quality of health care/
4. *safety/ or safety/st or safety management.mp.
5. Iatrogenic Disease/ or iatrogenic disease.mp.
6. quality assurance health care/
7. (patient safety or safety of patient$).mp.
8. *treatment outcome/
9. Patient$.ti
10. exp Physician-Patient Relations/
11. exp Patient Satisfaction/
12. or/1–11
13. workload/ or workload.mp. or overwork.mp.
14. exp professional competence/
15. work schedule tolerance/ or teamwork.tw.
16. “Personnel Staffing and Scheduling”/ or personnel staffing.mp.
17. Professional Autonomy/ or professional autonomy. mp.
18. professional power.mp.
19. exp Time Management/
20. or/13–19
21. 12 and 20
22. limit 21 to (english language and humans)
23. limit 22 to yr=”2000 -Current”
24. exp Physicians/
25. exp Nurse Practitioners/
26. exp Physician Assistants/
27. or/24–26
28. 23 and 27
29. limit 28 to (comment or editorial or letter or news)
30. 28 not 29

## Workflow

Database: Ovid MEDLINE(R)

1. exp Medical Errors/
2. (medical errors or medication errors or diagnostic errors).mp.
3. quality of health care/
4. *safety/ or safety/st or safety management.mp.
5. Iatrogenic Disease/ or iatrogenic disease.mp.
6. quality assurance health care/
7. (patient safety or safety of patient$).mp.
8. *treatment outcome/
9. Patient$.ti.
10. exp Physician-Patient Relations/
11. exp Patient Satisfaction/
12. or/1–11
13. exp Efficiency, Organizational/
14. exp “Task Performance and Analysis”/
15. exp Information Systems/
16. exp Electronic Health Records/
17. exp Equipment Design/
18. exp Equipment Safety/
19. Personnel Management/ or job performance.mp.
20. exp User-Computer Interface/
21. exp Expert Systems/
22. (distraction or interruption).mp.
23. multitask.mp.
24. paging.mp.
25. User-Computer Interface/ or human computer interactions.mp.
26. exp “Referral and Consultation”/
27. or/13–26
28. 12 and 27
29. limit 28 to (english language and humans)
30. limit 29 to yr=”2000-Current”
31. exp physicians/
32. exp nurse practitioners/ \
33. exp physician assistants/
34. or/31–33
35. 30 and 34
36. limit 35 to (comment or editorial or letter or news)
37. 35 not 36

## Organizational culture

Database: Ovid MEDLINE(R)

1. exp Medical Errors/
2. (medical errors or medication errors or diagnostic errors).mp.
3. quality of health care/
4. *safety/ or safety/st or safety management.mp.
5. Iatrogenic Disease/ or iatrogenic disease.mp.
6. quality assurance health care/
7. (patient safety or safety of patient$).mp.
8. *treatment outcome/
9. Patient$.ti.
10. exp Physician-Patient Relations/
11. exp Patient Satisfaction/
12. or/1–11
13. exp Interprofessional Relations/ or exp Organizational Culture/ or professional culture.mp.
14. organizational climate.mp.
15. exp Leadership/
16. management style.mp.
17. managerial style.mp.
18. skill mix.mp.
19. exp Models, Organizational/ or shared leadership. mp. or exp Organizational Innovation/
20. open door policies.mp.
21. exp Management Quality Circles/
22. exp Institutional Management Teams/
23. or/13–22
24. 12 and 23
25. limit 24 to (english language and humans)
26. limit 25 to yr=”2000 -Current”
27. exp physicians/
28. exp nurse practitioners/
29. exp physician assistants/
30. or/27–29
31. 26 and 30
32. limit 31 to (comment or editorial or letter or news)
33. 31 not 32

## Physical environment

Database: Ovid MEDLINE(R)

1. exp Medical Errors/
2. (medical errors or medication errors or diagnostic errors).mp
3. quality of health care/
4. *safety/ or safety/st or safety management.mp.
5. Iatrogenic Disease/ or iatrogenic disease.mp.
6. quality assurance health care/
7. (patient safety or safety of patient$).mp.
8. *treatment outcome/
9. Patient$.ti.
10. exp Physician-Patient Relations/
11. exp Patient Satisfaction/
12. or/1–11
13. exp Air Pollution/
14. exp Air Pollution, Indoor/
15. exp Light/ or exp Lighting/ or indoor lighting.mp.
16. exp Acoustics/
17. exp Noise/ or indoor noise.mp.
18. exp “Interior Design and Furnishings”/
19. exp Humidity/
20. exp Ventilation/ or exp Temperature/ or indoor temperature.mp. or exp Environmental Monitoring/
21. exp “Facility Design and Construction”/ or clinic design.mp
22. human factors engineering.mp.
23. exp Environment Design/ or facility environment. mp.
24. or/13–23
25. 12 and 24
26. limit 25 to (english language and humans)
27. limit 26 to yr=”2000-Current”
28. exp physicians/
29. exp nurse practitioners/
30. exp physician assistants/
31. or/28–30
32. 27 and 31
33. limit 32 to (comment or editorial or letter or news)
34. 32 not 33

## Team

Database: Ovid MEDLINE(R)

1. exp Patient Care Team/ or team-based.mp.
2. practice based care team.mp.
3. shared case.mp.
4. exp Interprofessional Relations/ or shared care.mp.
5. collaborative care.mp.
6. multidisciplinary care teams.mp.
7. multidisciplinary care team.mp.
8. 6 or 7
9. or/1–8
10. exp Medical Errors/
11. (medical errors or medication errors or diagnostic errors).mp.
12. quality of health care/
13. *safety/ or safety/st or safety management.mp.
14. Iatrogenic Disease/ or iatrogenic disease.mp.
15. quality assurance health care/
16. (patient safety or safety of patient$).mp.
17. *treatment outcome/
18. Patient$.ti.
19. exp Physician-Patient Relations/
20. exp Patient Satisfaction/
21. or/10–20
22. 9 and 21
23. limit 22 to (english language and humans)
24. limit 23 to yr=”2000 -Current”
25. exp Physicians/
26. exp Nurse Practitioners/
27. exp Physician Assistants/
28. or/25–27
29. 24 and 28
30. limit 29 to (comment or editorial or letter or news)
31. 29 not 30