# References

1 U.S. Department of Health and Human Services. Health Resources & Services Adminstration: Telehealth Programs. Available at https://www.hrsa.gov/rural-health/telehealth/index.html. Accessed November 8, 2017.
2 Weinstein RS, Lopez AM, Joseph BA, . Telemedicine, telehealth, and mobile health applications that work: opportunities and barriers. Am J Med. 2014;127(3):183–187.24384059
3 Atkins D, Cullen T. The future of health information technology: implications for research. Med Care. 2013;51(3 Suppl 1):S1–3.
4 Tuerk PW, Fortney J, Bosworth HB, . Toward the development of national telehealth services: the role of Veterans Health Administration and future directions for research. Telemed J E Health. 2010;16(1):115–117.20043704
5 Veterans Health Administration. Blueprint for Excellence. September 21, 2014. Available at: https://www.va.gov/HEALTH/docs/VHA_Blueprint_for_Excellence.pdf. Accessed August 9, 2017.
6 Department of Veterans Affairs. VA Telehealth Services. Available at: https://www.telehealth.va.gov/. Accessed August 9, 2017.
7 Department of Veterans Affairs. Connected Care. Website. Available at: https://connectedcare.va.gov/. Accessed November 2, 2017.
8 Frayne SM, Mattocks KM. Sourcebook: Women Veterans in the Veterans Health Administration. Volume 2: Sociodemographics and Use of VHA and Non-VA Care (Fee). 2012. Available at: https://works.bepress.com/kristin_mattocks/20/. Accessed August 8, 2017.
9 Cordasco KM, Mengeling MA, Yano EM, Washington DL. Health and Health Care Access of Rural Women Veterans: Findings From the National Survey of Women Veterans. J Rural Health. 2016;32(4):397–406.27466970
10 Washington DL, Bean-Mayberry B, Hamilton AB, Cordasco KM, Yano EM. Women veterans’ healthcare delivery preferences and use by military service era: findings from the National Survey of Women Veterans. J Gen Intern Med. 2013;28 Suppl 2:S571–576.23807067
11 deKleijn M, Lagro-Janssen AL, Canelo I, Yano EM. Creating a roadmap for delivering gender-sensitive comprehensive care for women Veterans: results of a national expert panel. Med Care. 2015;53(4 Suppl 1):S156–164.25767971
12 Cordasco KM, Zuchowski JL, Hamilton AB, . Early lessons learned in implementing a women’s health educational and virtual consultation program in VA. Med Care. 2015;53(4 Suppl 1):S88–92.25767983
13 Mattocks KM, Kuzdeba J, Baldor R, Casares J, Lombardini L, Gerber MR. Implementing and Evaluating a Telephone-Based Centralized Maternity Care Coordination Program for Pregnant Veterans in the Department of Veterans Affairs. Womens Health Issues. 2017.
14 Miake-Lye IM, Hempel S, Shanman R, Shekelle PG. What is an evidence map? A systematic review of published evidence maps and their definitions, methods, and products. Syst Rev. 2016;5:28.26864942
15 Duan-Porter W, Goldstein KM, McDuffie JR, . Reporting of Sex Effects by Systematic Reviews on Interventions for Depression, Diabetes, and Chronic Pain. Ann Intern Med. 2016;165(3):184–193.27111355
16 EPOC. Effective Practice and Organisation of Care (EPOC). EPOC Resources for review authors. Oslo: Norwegian Knowledge Centre for the Health Services; 2015. Available at: http://epoc.cochrane.org/resources/epoc-resources-review-authors. Accessed November 3, 2017.
17 Simmons D, Devlieger R, van Assche A, . Effect of physical activity and/or healthy eating on GDM risk: The DALI Lifestyle Study. J Clin Endocrinol Metab. 2016:jc20163455.
18 Wilbur J, Miller AM, Fogg L, . Randomized Clinical Trial of the Women’s Lifestyle Physical Activity Program for African-American Women: 24- and 48-Week Outcomes. Am J Health Promot. 2016;30(5):335–345.27404642
19 Tso LS, Loi D, Mosley DG, . Evaluation of a Nationwide Pharmacist-Led Phone Outreach Program to Improve Osteoporosis Management in Older Women with Recently Sustained Fractures. J Manag Care Spec Pharm. 2015;21(9):803–810.26308227
20 Freeman LW, White R, Ratcliff CG, . A randomized trial comparing live and telemedicine deliveries of an imagery-based behavioral intervention for breast cancer survivors: reducing symptoms and barriers to care. Psychooncology. 2015;24(8):910–918.25146413
21 Reeder JA, Joyce T, Sibley K, Arnold D, Altindag O. Telephone peer counseling of breastfeeding among WIC participants: a randomized controlled trial. Pediatrics. 2014;134(3):e700–709.25092936
22 Snaith VJ, Hewison J, Steen IN, Robson SC. Antenatal telephone support intervention with and without uterine artery Doppler screening for low risk nulliparous women: a randomised controlled trial. BMC Pregnancy Childbirth. 2014;14:121.24685072
23 Baker TB, Hawkins R, Pingree S, . Optimizing eHealth breast cancer interventions: which types of eHealth services are effective? Transl Behav Med. 2011;1(1):134–145.21709810
24 Kimman ML, Dirksen CD, Voogd AC, . Economic evaluation of four follow-up strategies after curative treatment for breast cancer: results of an RCT. Eur J Cancer. 2011;47(8):1175–1185.21257305
25 Kimman ML, Dirksen CD, Voogd AC, . Nurse-led telephone follow-up and an educational group programme after breast cancer treatment: results of a 2 × 2 randomised controlled trial. Eur J Cancer. 2011;47(7):1027–1036.21237636
26 Hawkins RP, Pingree S, Shaw B, . Mediating processes of two communication interventions for breast cancer patients. Patient Educ Couns. 2010;81 Suppl:S48–53.21081261
27 Sherman DW, Haber J, Hoskins CN, . The effects of psychoeducation and telephone counseling on the adjustment of women with early-stage breast cancer. Appl Nurs Res. 2012;25(1):3–16.20974079
28 Sandgren AK, McCaul KD. Long-term telephone therapy outcomes for breast cancer patients. Psychooncology. 2007;16(1):38–47.16862634
29 Dietrich AJ, Tobin JN, Cassells A, . Telephone care management to improve cancer screening among low-income women: a randomized, controlled trial. Ann Intern Med. 2006;144(8):563–571.16618953
30 Conn VS, Burks KJ, Minor MA, Mehr DR. Randomized trial of 2 interventions to increase older women’s exercise. Am J Health Behav. 2003;27(4):380–388.12882432
31 Samarel N, Tulman L, Fawcett J. Effects of two types of social support and education on adaptation to early-stage breast cancer. Res Nurs Health. 2002;25(6):459–470.12424783
32 Valanis BG, Glasgow RE, Mullooly J, . Screening HMO women overdue for both mammograms and pap tests. Prev Med. 2002;34(1):40–50.11749095
33 Ershoff DH, Quinn VP, Boyd NR, Stern J, Gregory M, Wirtschafter D. The Kaiser Permanente prenatal smoking-cessation trial: when more isn’t better, what is enough? Am J Prev Med. 1999;17(3):161–168.10987630
34 Hawkins RP, Pingree S, Baker TB, . Integrating eHealth with human services for breast cancer patients. Transl Behav Med. 2011;1(1):146–154.22496712
35 Ahmed AH, Roumani AM, Szucs K, Zhang L, King D. The Effect of Interactive Web-Based Monitoring on Breastfeeding Exclusivity, Intensity, and Duration in Healthy, Term Infants After Hospital Discharge. J Obstet Gynecol Neonatal Nurs. 2016;45(2):143–154.
36 Albright CL, Steffen AD, Wilkens LR, . Effectiveness of a 12-month randomized clinical trial to increase physical activity in multiethnic postpartum women: results from Hawaii’s Na Mikimiki Project. Prev Med. 2014;69:214–223.25285751
37 Alemi F, Stephens RC, Javalghi RG, Dyches H, Butts J, Ghadiri A. A randomized trial of a telecommunications network for pregnant women who use cocaine. Med Care. 1996;34(10 Suppl):Os10–20.8843933
38 Althuizen E, van der Wijden CL, van Mechelen W, Seidell JC, van Poppel MN. The effect of a counselling intervention on weight changes during and after pregnancy: a randomised trial. BJOG. 2013;120(1):92–99.23121074
39 Amiri P, Hamzavi-Zarghani N, Nazeri P, . Can an educational intervention improve iodine nutrition status in pregnant women? A randomized controlled trial. Thyroid. 2016.
40 Bagherinia M, Mirghafourvand M, Shafaie FS. The effect of educational package on functional status and maternal self-confidence of primiparous women in postpartum period: a randomized controlled clinical trial. J Matern Fetal Neonatal Med. 2016:1–22.
41 Brooten D, Youngblut JM, Brown L, Finkler SA, Neff DF, Madigan E. A randomized trial of nurse specialist home care for women with high-risk pregnancies: outcomes and costs. Am J Manag Care. 2001;7(8):793–803.11519238
42 Bryce RL, Stanley FJ, Garner JB. Randomized controlled trial of antenatal social support to prevent preterm birth. Br J Obstet Gynaecol. 1991;98(10):1001–1008.1751431
43 Bunik M, Shobe P, O’Connor ME, . Are 2 weeks of daily breastfeeding support insufficient to overcome the influences of formula? Acad Pediatr. 2010;10(1):21–28.20129478
44 Carlsen EM, Kyhnaeb A, Renault KM, Cortes D, Michaelsen KF, Pryds O. Telephone-based support prolongs breastfeeding duration in obese women: a randomized trial. Am J Clin Nutr. 2013;98(5):1226–1232.24004897
45 Chapman DJ, Damio G, Young S, Perez-Escamilla R. Effectiveness of breastfeeding peer counseling in a low-income, predominantly Latina population: a randomized controlled trial. Arch Pediatr Adolesc Med. 2004;158(9):897–902.15351756
46 Cummins SE, Tedeschi GJ, Anderson CM, Zhu SH. Telephone Intervention for Pregnant Smokers: A Randomized Controlled Trial. Am J Prev Med. 2016;51(3):318–326.27056131
47 Cupples ME, Stewart MC, Percy A, Hepper P, Murphy C, Halliday HL. A RCT of peer-mentoring for first-time mothers in socially disadvantaged areas (the MOMENTS Study). Arch Dis Child. 2011;96(3):252–258.20522466
48 Curry MA, Durham L, Bullock L, Bloom T, Davis J. Nurse case management for pregnant women experiencing or at risk for abuse. J Obstet Gynecol Neonatal Nurs. 2006;35(2):181–192.
49 Dalfra MG, Nicolucci A, Lapolla A. The effect of telemedicine on outcome and quality of life in pregnant women with diabetes. J Telemed Telecare. 2009;15(5):238–242.19590029
50 Dennis CL. Breastfeeding peer support: maternal and volunteer perceptions from a randomized controlled trial. Birth. 2002;29(3):169–176.12153647
51 Dennis CL, Hodnett E, Gallop R, Chalmers B. The effect of peer support on breast-feeding duration among primiparous women: a randomized controlled trial. CMAJ. 2002;166(1):21–28.11800243
52 Dennis CL, Hodnett E, Kenton L, . Effect of peer support on prevention of postnatal depression among high risk women: multisite randomised controlled trial. BMJ. 2009;338:a3064.19147637
53 Dodd JM, Turnbull D, McPhee AJ, . Antenatal lifestyle advice for women who are overweight or obese: LIMIT randomised trial. BMJ. 2014;348:g1285.24513442
54 Dornelas EA, Magnavita J, Beazoglou T, . Efficacy and cost-effectiveness of a clinic-based counseling intervention tested in an ethnically diverse sample of pregnant smokers. Patient Educ Couns. 2006;64(1-3):342–349.16859864
55 Eden KB, Perrin NA, Vesco KK, Guise JM. A randomized comparative trial of two decision tools for pregnant women with prior cesareans. J Obstet Gynecol Neonatal Nurs. 2014;43(5):568–579.
56 Efrat MW, Esparza S, Mendelson SG, Lane CJ. The effect of lactation educators implementing a telephone-based intervention among low-income Hispanics: A randomised trial. Health Educ J. 2015;74(4):424–441.26941454
57 Fenwick J, Toohill J, Gamble J, . Effects of a midwife psycho-education intervention to reduce childbirth fear on women’s birth outcomes and postpartum psychological wellbeing. BMC Pregnancy Childbirth. 2015;15:284.26518597
58 Ferrara A, Hedderson MM, Brown SD, . The Comparative Effectiveness of Diabetes Prevention Strategies to Reduce Postpartum Weight Retention in Women With Gestational Diabetes Mellitus: The Gestational Diabetes’ Effects on Moms (GEM) Cluster Randomized Controlled Trial. Diabetes Care. 2016;39(1):65–74.26657945
59 Frank DA, Wirtz SJ, Sorenson JR, Heeren T. Commercial discharge packs and breast-feeding counseling: effects on infant-feeding practices in a randomized trial. Pediatrics. 1987;80(6):845–854.3684395
60 Fu IC, Fong DY, Heys M, Lee IL, Sham A, Tarrant M. Professional breastfeeding support for first-time mothers: a multicentre cluster randomised controlled trial. BJOG. 2014;121(13):1673–1683.24861802
61 Gagnon AJ, Edgar L, Kramer MS, Papageorgiou A, Waghorn K, Klein MC. A randomized trial of a program of early postpartum discharge with nurse visitation. Am J Obstet Gynecol. 1997;176(1 Pt 1):205–211.9024115
62 Gamble J, Creedy D, Moyle W, Webster J, McAllister M, Dickson P. Effectiveness of a counseling intervention after a traumatic childbirth: a randomized controlled trial. Birth. 2005;32(1):11–19.15725200
63 Gao LL, Chan SW, Li X, Chen S, Hao Y. Evaluation of an interpersonal-psychotherapy-oriented childbirth education programme for Chinese first-time childbearing women: a randomised controlled trial. Int J Nurs Stud. 2010;47(10):1208–1216.20362992
64 Gao LL, Chan SW, Sun K. Effects of an interpersonal-psychotherapy-oriented childbirth education programme for Chinese first-time childbearing women at 3-month follow up: randomised controlled trial. Int J Nurs Stud. 2012;49(3):274–281.21962336
65 Gao LL, Xie W, Yang X, Chan SW. Effects of an interpersonal-psychotherapy-oriented postnatal programme for Chinese first-time mothers: a randomized controlled trial. Int J Nurs Stud. 2015;52(1):22–29.24994573
66 Giallo R, Cooklin A, Dunning M, Seymour M. The efficacy of an intervention for the management of postpartum fatigue. J Obstet Gynecol Neonatal Nurs. 2014;43(5):598–613.
67 Gu Y, Zhu Y, Zhang Z, Wan H. Effectiveness of a theory-based breastfeeding promotion intervention on exclusive breastfeeding in China: A randomised controlled trial. Midwifery. 2016;42:93–99.27788416
68 Hannan J, Brooten D, Page T, Galindo A, Torres M. Low-Income First-Time Mothers: Effects of APN Follow-up Using Mobile Technology on Maternal and Infant Outcomes. Glob Pediatr Health. 2016;3:2333794x16660234.
69 Hannover W, Thyrian JR, Roske K, . Smoking cessation and relapse prevention for postpartum women: results from a randomized controlled trial at 6, 12, 18 and 24 months. Addict Behav. 2009;34(1):1–8.18804331
70 Hillesund ER, Bere E, Sagedal LR, Vistad I, Overby NC. Effect of a diet intervention during pregnancy on dietary behavior in the randomized controlled Norwegian Fit for Delivery study. J Dev Orig Health Dis. 2016;7(5):538–547.27307037
71 Huang CM, Wu HL, Huang SH, Chien LY, Guo JL. Transtheoretical model-based passive smoking prevention programme among pregnant women and mothers of young children. Eur J Public Health. 2013;23(5):777–782.23325124
72 Janssen PA, Desmarais SL. Women’s experience with early labour management at home vs. in hospital: a randomised controlled trial. Midwifery. 2013;29(3):190–194.22901494
73 Janssen PA, Still DK, Klein MC, . Early labor assessment and support at home versus telephone triage: a randomized controlled trial. Obstet Gynecol. 2006;108(6):1463–1469.17138781
74 Jiang H, Li M, Wen LM, . Effect of short message service on infant feeding practice: findings from a community-based study in Shanghai, China. JAMA Pediatr. 2014;168(5):471–478.24639004
75 Jiang L, Wang ZZ, Qiu LR, Wan GB, Lin Y, Wei Z. Psychological intervention for postpartum depression. J Huazhong Univ Sci Technolog Med Sci. 2014;34(3):437–442.24939313
76 Jordan ET, Bushar JA, Kendrick JS, Johnson P, Wang J. Encouraging Influenza Vaccination Among Text4baby Pregnant Women and Mothers. Am J Prev Med. 2015;49(4):563–572.26232904
77 Kamalifard M, Yavarikia P, Babapour Kheiroddin J, Salehi Pourmehr H, Iraji Iranagh R. The effect of peers support on postpartum depression: a single-blind randomized clinical trial. J Caring Sci. 2013;2(3):237–244.25276732
78 Lewis BA, Gjerdingen DK, Avery MD, . A randomized trial examining a physical activity intervention for the prevention of postpartum depression: The healthy mom trial. Mental Health and Physical Activity. 2014;7(1):42–49.
79 Lund S, Hemed M, Nielsen BB, . Mobile phones as a health communication tool to improve skilled attendance at delivery in Zanzibar: a cluster-randomised controlled trial. BJOG. 2012;119(10):1256–1264.22805598
80 Mangwi Ayiasi R, Kolsteren P, Batwala V, Criel B, Orach CG. Effect of Village Health Team Home Visits and Mobile Phone Consultations on Maternal and Newborn Care Practices in Masindi and Kiryandongo, Uganda: A Community-Intervention Trial. PLoS One. 2016;11(4):e0153051.27101379
81 Maslowsky J, Frost S, Hendrick CE, Trujillo Cruz FO, Merajver SD. Effects of postpartum mobile phone-based education on maternal and infant health in Ecuador. Int J Gynaecol Obstet. 2016;134(1):93–98.27126905
82 McBride CM, Baucom DH, Peterson BL, . Prenatal and postpartum smoking abstinence a partner-assisted approach. Am J Prev Med. 2004;27(3):232–238.15450636
83 Milgrom J, Schembri C, Ericksen J, Ross J, Gemmill AW. Towards parenthood: an antenatal intervention to reduce depression, anxiety and parenting difficulties. J Affect Disord. 2011;130(3):385–394.21112641
84 Mohammad-Alizadeh-Charandabi S, Malakoti J, Sohrabi F, Shokranian N. The effect of telephone support on postpartum depression: a randomized controlled trial. J Caring Sci. 2013;2(2):147–155.25276721
85 Moore ML, Meis PJ, Ernest JM, Wells HB, Zaccaro DJ, Terrell T. A randomized trial of nurse intervention to reduce preterm and low birth weight births. Obstet Gynecol. 1998;91(5 Pt 1):656–661.9572206
86 Muender MM, Moore ML, Chen GJ, Sevick MA. Cost-benefit of a nursing telephone intervention to reduce preterm and low-birthweight births in an African American clinic population. Prev Med. 2000;30(4):271–276.10731454
87 Naughton F, Prevost AT, Gilbert H, Sutton S. Randomized controlled trial evaluation of a tailored leaflet and SMS text message self-help intervention for pregnant smokers (MiQuit). Nicotine Tob Res. 2012;14(5):569–577.22311960
88 Ngai FW, Wong PW, Leung KY, Chau PH, Chung KF. The Effect of Telephone-Based Cognitive-Behavioral Therapy on Postnatal Depression: A Randomized Controlled Trial. Psychother Psychosom. 2015;84(5):294–303.26278623
89 Ngai FW, Wong PWC, Chung KF, . The effect of telephone-based cognitive-behavioural therapy on parenting stress: A randomised controlled trial. J Psychosom Res. 2016;86:34–38.27302544
90 Niela-Vilen H, Axelin A, Melender HL, Loyttyniemi E, Salantera S. Breastfeeding preterm infants - a randomized controlled trial of the effectiveness of an Internet-based peer-support group. J Adv Nurs. 2016;72(10):2495–2507.27136894
91 Oakley A, Rajan L, Grant A. Social support and pregnancy outcome. Br J Obstet Gynaecol. 1990;97(2):155–162.2317466
92 Odeny TA, Bukusi EA, Cohen CR, Yuhas K, Camlin CS, McClelland RS. Texting improves testing: a randomized trial of two-way SMS to increase postpartum prevention of mother-to-child transmission retention and infant HIV testing. Aids. 2014;28(15):2307–2312.25313586
93 O’Reilly SL, Dunbar JA, Versace V, . Mothers after Gestational Diabetes in Australia (MAGDA): A Randomised Controlled Trial of a Postnatal Diabetes Prevention Program. PLoS Med. 2016;13(7):e1002092.27459502
94 Ostbye T, Krause KM, Lovelady CA, . Active Mothers Postpartum: a randomized controlled weight-loss intervention trial. Am J Prev Med. 2009;37(3):173–180.19595557
95 Phelan S, Phipps MG, Abrams B, . Does behavioral intervention in pregnancy reduce postpartum weight retention? Twelve-month outcomes of the Fit for Delivery randomized trial. Am J Clin Nutr. 2014;99(2):302–311.24284438
96 Phelan S, Phipps MG, Abrams B, Darroch F, Schaffner A, Wing RR. Randomized trial of a behavioral intervention to prevent excessive gestational weight gain: the Fit for Delivery Study. Am J Clin Nutr. 2011;93(4):772–779.21310836
97 Sagedal LR, Overby NC, Bere E, . Lifestyle intervention to limit gestational weight gain: the Norwegian Fit for Delivery randomised controlled trial. BJOG. 2017;124(1):97–109.26768233
98 Sagedal LR, Øverby NC, Bere E, . Lifestyle intervention to limit gestational weight gain: The Norwegian Fit for Delivery randomised controlled trial. BJOG. 2016.
99 Sagedal LR, Sanda B, Overby NC, . The effect of prenatal lifestyle intervention on weight retention 12 months postpartum: results of the Norwegian Fit for Delivery randomised controlled trial. BJOG. 2017;124(1):111–121.26786294
100 Seguranyes G, Costa D, Fuentelsaz-Gallego C, . Efficacy of a videoconferencing intervention compared with standard postnatal care at primary care health centres in Catalonia. Midwifery. 2014;30(6):764–771.24016553
101 Serwint JR, Wilson MH, Duggan AK, Mellits ED, Baumgardner RA, DeAngelis C. Do postpartum nursery visits by the primary care provider make a difference? Pediatrics. 1991;88(3):444–449.1881721
102 Srinivas GL, Benson M, Worley S, Schulte E. A clinic-based breastfeeding peer counselor intervention in an urban, low-income population: interaction with breastfeeding attitude. J Hum Lact. 2015;31(1):120–128.25193602
103 Stotts AL, Diclemente CC, Dolan-Mullen P. One-to-one: a motivational intervention for resistant pregnant smokers. Addict Behav. 2002;27(2):275–292.11817768
104 Surkan PJ, Gottlieb BR, McCormick MC, Hunt A, Peterson KE. Impact of a health promotion intervention on maternal depressive symptoms at 15 months postpartum. Matern Child Health J. 2012;16(1):139–148.21153759
105 Tahir NM, Al-Sadat N. Does telephone lactation counselling improve breastfeeding practices? A randomised controlled trial. Int J Nurs Stud. 2013;50(1):16–25.23084438
106 Takeuchi S, Horiuchi S. Randomised controlled trial using smartphone website vs leaflet to support antenatal perineal massage practice for pregnant women. Women Birth. 2016;29(5):430–435.26906970
107 Toohill J, Fenwick J, Gamble J, . A randomized controlled trial of a psycho-education intervention by midwives in reducing childbirth fear in pregnant women. Birth. 2014;41(4):384–394.25303111
108 Wang X, Li GY, Deng ML, . Pelvic floor muscle training as a persistent nursing intervention: Effect on delivery outcome and pelvic floor myodynamia. International Journal of Nursing Sciences. 2014;1(1):48–52.
109 Wilton G, Moberg DP, Van Stelle KR, Dold LL, Obmascher K, Goodrich J. A randomized trial comparing telephone versus in-person brief intervention to reduce the risk of an alcohol-exposed pregnancy. J Subst Abuse Treat. 2013;45(5):389–394.23891460
110 Wong EH, Nelson E, Choi KC, Wong KP, Ip C, Ho LC. Evaluation of a peer counselling programme to sustain breastfeeding practice in Hong Kong. Int Breastfeed J. 2007;2:12.17883851
111 Bartholomew LM, Soules K, Church K, . Managing diabetes in pregnancy using cell phone/internet technology. Clinical Diabetes. 2015;33(4):169–174.26487790
112 Lee EW, Denison FC, Hor K, Reynolds RM. Web-based interventions for prevention and treatment of perinatal mood disorders: a systematic review. BMC Pregnancy Childbirth. 2016;16:38.26928898
113 Annesi JJ. Mediation of the relationship of behavioural treatment type and changes in psychological predictors of healthy eating by body satisfaction changes in women with obesity. Obes Res Clin Pract. 2016.
114 Befort CA, Klemp JR, Sullivan DK, . Weight loss maintenance strategies among rural breast cancer survivors: The rural women connecting for better health trial. Obesity (Silver Spring). 2016;24(10):2070–2077.27581328
115 Bloom JR, Stewart SL, Hancock SL. Breast cancer screening in women surviving Hodgkin disease. Am J Clin Oncol. 2006;29(3):258–266.16755179
116 Bullock L, Everett KD, Mullen PD, Geden E, Longo DR, Madsen R. Baby BEEP: A randomized controlled trial of nurses’ individualized social support for poor rural pregnant smokers. Matern Child Health J. 2009;13(3):395–406.18496746
117 Cadmus-Bertram L, Nelson SH, Hartman S, Patterson RE, Parker BA, Pierce JP. Randomized trial of a phone- and web-based weight loss program for women at elevated breast cancer risk: the HELP study. J Behav Med. 2016;39(4):551–559.27012848
118 Chen AH, Sallis JF, Castro CM, . A home-based behavioral intervention to promote walking in sedentary ethnic minority women: project WALK. Womens Health. 1998;4(1):19–39.9520605
119 Conway TL, Woodruff SI, Edwards CC, Elder JP, Hurtado SL, Hervig LK. Operation Stay Quit: evaluation of two smoking relapse prevention strategies for women after involuntary cessation during US Navy recruit training. Mil Med. 2004;169(3):236–242.15080246
120 Corkrey R, Parkinson L, Bates L. Pressing the key pad: trial of a novel approach to health promotion advice. Prev Med. 2005;41(2):657–666.15917066
121 Curry SJ, Ludman EJ, Graham E, Stout J, Grothaus L, Lozano P. Pediatric-based smoking cessation intervention for low-income women: a randomized trial. Arch Pediatr Adolesc Med. 2003;157(3):295–302.12622686
122 Demark-Wahnefried W, Colditz GA, Rock CL, . Quality of life outcomes from the Exercise and Nutrition Enhance Recovery and Good Health for You (ENERGY)-randomized weight loss trial among breast cancer survivors. Breast Cancer Res Treat. 2015;154(2):329–337.26518022
123 Dietrich AJ, Tobin JN, Cassells A, . Translation of an efficacious cancer-screening intervention to women enrolled in a Medicaid managed care organization. Ann Fam Med. 2007;5(4):320–327.17664498
124 Dietrich AJ, Tobin JN, Robinson CM, . Telephone outreach to increase colon cancer screening in medicaid managed care organizations: a randomized controlled trial. Ann Fam Med. 2013;11(4):335–343.23835819
125 Eaker S, Adami HO, Granath F, Wilander E, Sparen P. A large population-based randomized controlled trial to increase attendance at screening for cervical cancer. Cancer Epidemiol Biomarkers Prev. 2004;13(3):346–354.15006907
126 Eakin EG, Lawler SP, Winkler EA, Hayes SC. A randomized trial of a telephone-delivered exercise intervention for non-urban dwelling women newly diagnosed with breast cancer: exercise for health. Ann Behav Med. 2012;43(2):229–238.22109352
127 Fjeldsoe BS, Miller YD, Graves N, Barnett AG, Marshall AL. Randomized Controlled Trial of an Improved Version of MobileMums, an Intervention for Increasing Physical Activity in Women with Young Children. Ann Behav Med. 2015;49(4):487–499.25582987
128 Goodwin PJ, Segal RJ, Vallis M, . Randomized trial of a telephone-based weight loss intervention in postmenopausal women with breast cancer receiving letrozole: the LISA trial. J Clin Oncol. 2014;32(21):2231–2239.24934783
129 Gordon LG, DiSipio T, Battistutta D, . Cost-effectiveness of a pragmatic exercise intervention for women with breast cancer: results from a randomized controlled trial. Psychooncology. 2016.
130 Han HR, Song Y, Kim M, . Breast and Cervical Cancer Screening Literacy Among Korean American Women: A Community Health Worker-Led Intervention. Am J Public Health. 2017;107(1):159–165.27854539
131 Harrigan M, Cartmel B, Loftfield E, . Randomized Trial Comparing Telephone Versus In-Person Weight Loss Counseling on Body Composition and Circulating Biomarkers in Women Treated for Breast Cancer: The Lifestyle, Exercise, and Nutrition (LEAN) Study. J Clin Oncol. 2016;34(7):669–676.26598750
132 Hayes S, Rye S, Battistutta D, . Design and implementation of the Exercise for Health trial -- a pragmatic exercise intervention for women with breast cancer. Contemp Clin Trials. 2011;32(4):577–585.21463707
133 Hayes SC, Rye S, Disipio T, . Exercise for health: a randomized, controlled trial evaluating the impact of a pragmatic, translational exercise intervention on the quality of life, function and treatment-related side effects following breast cancer. Breast Cancer Res Treat. 2013;137(1):175–186.23139058
134 Helmes AW, Culver JO, Bowen DJ. Results of a randomized study of telephone versus in-person breast cancer risk counseling. Patient Educ Couns. 2006;64(1-3):96–103.16427245
135 Hou SI. Stage of adoption and impact of direct-mail communications with and without phone intervention on Chinese women’s cervical smear screening behavior. Prev Med. 2005;41(3-4):749–756.16120455
136 Kerr J, Patrick K, Norman G, . Randomized control trial of a behavioral intervention for overweight women: impact on depressive symptoms. Depress Anxiety. 2008;25(7):555–558.17557319
137 Keyserling TC, Samuel Hodge CD, Jilcott SB, . Randomized trial of a clinic-based, community-supported, lifestyle intervention to improve physical activity and diet: the North Carolina enhanced WISEWOMAN project. Prev Med. 2008;46(6):499–510.18394692
138 Keyserling TC, Samuel-Hodge CD, Ammerman AS, . A randomized trial of an intervention to improve self-care behaviors of African-American women with type 2 diabetes: impact on physical activity. Diabetes Care. 2002;25(9):1576–1583.12196430
139 Koniak-Griffin D, Brecht ML, Takayanagi S, Villegas J, Melendrez M, Balcazar H. A community health worker-led lifestyle behavior intervention for Latina (Hispanic) women: feasibility and outcomes of a randomized controlled trial. Int J Nurs Stud. 2015;52(1):75–87.25307195
140 Lawton BA, Rose SB, Elley CR, Dowell AC, Fenton A, Moyes SA. Exercise on prescription for women aged 40-74 recruited through primary care: two year randomised controlled trial. BMJ. 2008;337:a2509.19074218
141 Lawton BA, Rose SB, Elley CR, . Exercise on prescription for women aged 40-74 recruited through primary care: Two year randomised controlled trial. BMJ. 2009;(2009) 338(7686):88–91.
142 Lee RE, Goldberg JH, Sallis JF, Hickmann SA, Castro CM, Chen AH. A prospective analysis of the relationship between walking and mood in sedentary ethnic minority women. Women Health. 2001;32(4):1–15.
143 Lopez-Torres Hidalgo J, Sanchez Ortiz MP, Rabanales Sotos J, Simarro Herraez MJ, Lopez-Torres Lopez J, Campos Rosa M. Effectiveness of three interventions in improving adherence to cervical cancer screening. Eur J Cancer Prev. 2016;25(5):423–429.26301923
144 Manfredi C, Crittenden KS, Cho YI, Gao S. Long-term effects (up to 18 months) of a smoking cessation program among women smokers in public health clinics. Prev Med. 2004;38(1):10–19.14672637
145 Maskarinec G, Robbins C, Riola B, Kane-Sample L, Franke AA, Murphy S. Three measures show high compliance in a soy intervention among premenopausal women. J Am Diet Assoc. 2003;103(7):861–866.12830025
146 McBride CM, Scholes D, Grothaus LC, Curry SJ, Ludman E, Albright J. Evaluation of a minimal self-help smoking cessation intervention following cervical cancer screening. Prev Med. 1999;29(2):133–138.10446040
147 McClure JB, Westbrook E, Curry SJ, Wetter DW. Proactive, motivationally enhanced smoking cessation counseling among women with elevated cervical cancer risk. Nicotine Tob Res. 2005;7(6):881–889.16298723
148 Miller SM, Siejak KK, Schroeder CM, Lerman C, Hernandez E, Helm CW. Enhancing adherence following abnormal Pap smears among low-income minority women: a preventive telephone counseling strategy. J Natl Cancer Inst. 1997;89(10):703–708.9168185
149 Nies MA, Chruscial HL, Hepworth JT. An intervention to promote walking in sedentary women in the community. Am J Health Behav. 2003;27(5):524–535.14521248
150 Parra-Medina D, Wilcox S, Salinas J, . Results of the Heart Healthy and Ethnically Relevant Lifestyle trial: a cardiovascular risk reduction intervention for African American women attending community health centers. Am J Public Health. 2011;101(10):1914–1921.21852629
151 Paskett ED, McLaughlin JM, Lehman AM, Katz ML, Tatum CM, Oliveri JM. Evaluating the efficacy of lay health advisors for increasing risk-appropriate Pap test screening: a randomized controlled trial among Ohio Appalachian women. Cancer Epidemiol Biomarkers Prev. 2011;20(5):835–843.21430302
152 Peshkin BN, Kelly S, Nusbaum RH, . Patient Perceptions of Telephone vs. In-Person BRCA1/BRCA2 Genetic Counseling. J Genet Couns. 2016;25(3):472–482.26455498
153 Pierce JP, Natarajan L, Sun S, . Increases in plasma carotenoid concentrations in response to a major dietary change in the women’s healthy eating and living study. Cancer Epidemiol Biomarkers Prev. 2006;15(10):1886–1892.17035395
154 Pierce JP, Newman VA, Flatt SW, . Telephone counseling intervention increases intakes of micronutrient- and phytochemical-rich vegetables, fruit and fiber in breast cancer survivors. J Nutr. 2004;134(2):452–458.14747688
155 Pinto BM, Papandonatos GD, Goldstein MG. A randomized trial to promote physical activity among breast cancer patients. Health Psychol. 2013;32(6):616–626.23730723
156 Rigotti NA, Park ER, Regan S, . Efficacy of telephone counseling for pregnant smokers: a randomized controlled trial. Obstet Gynecol. 2006;108(1):83–92.16816060
157 Rimer BK, Conaway M, Lyna P, . The impact of tailored interventions on a community health center population. Patient Educ Couns. 1999;37(2):125–140.14528540
158 Rock CL, Flatt SW, Byers TE, . Results of the Exercise and Nutrition to Enhance Recovery and Good Health for You (ENERGY) Trial: A Behavioral Weight Loss Intervention in Overweight or Obese Breast Cancer Survivors. J Clin Oncol. 2015;33(28):3169–3176.26282657
159 Rock CL, Flatt SW, Sherwood NE, Karanja N, Pakiz B, Thomson CA. Effect of a free prepared meal and incentivized weight loss program on weight loss and weight loss maintenance in obese and overweight women: a randomized controlled trial. Jama. 2010;304(16):1803–1810.20935338
160 Sivarajan Froelicher ES, Miller NH, Christopherson DJ, . High rates of sustained smoking cessation in women hospitalized with cardiovascular disease: the Women’s Initiative for Nonsmoking (WINS). Circulation. 2004;109(5):587–593.14769679
161 Solomon LJ, Marcy TW, Howe KD, Skelly JM, Reinier K, Flynn BS. Does extended proactive telephone support increase smoking cessation among low-income women using nicotine patches? Prev Med. 2005;40(3):306–313.15533544
162 Stein K, Lewendon G, Jenkins R, Davis C. Improving uptake of cervical cancer screening in women with prolonged history of non-attendance for screening: a randomized trial of enhanced invitation methods. J Med Screen. 2005;12(4):185–189.16417695
163 Steinberg DM, Levine EL, Lane I, . Adherence to self-monitoring via interactive voice response technology in an eHealth intervention targeting weight gain prevention among Black women: randomized controlled trial. J Med Internet Res. 2014;16(4):e114.24780934
164 Wetter DW, McClure JB, Cofta-Woerpel L, . A randomized clinical trial of a palmtop computer-delivered treatment for smoking relapse prevention among women. Psychol Addict Behav. 2011;25(2):365–371.21500879
165 Allard NC. Day surgery for breast cancer: effects of a psychoeducational telephone intervention on functional status and emotional distress. Oncol Nurs Forum. 2007;34(1):133–141.17562640
166 Aranda S, Schofield P, Weih L, Milne D, Yates P, Faulkner R. Meeting the support and information needs of women with advanced breast cancer: a randomised controlled trial. Br J Cancer. 2006;95(6):667–673.16967054
167 Ashing K, Rosales M. A telephonic-based trial to reduce depressive symptoms among Latina breast cancer survivors. Psychooncology. 2014;23(5):507–515.24217994
168 Bastani R, Mojica CM, Berman BA, Ganz PA. Low-income women with abnormal breast findings: results of a randomized trial to increase rates of diagnostic resolution. Cancer Epidemiol Biomarkers Prev. 2010;19(8):1927–1936.20647406
169 Budin WC, Hoskins CN, Haber J, . Breast cancer: education, counseling, and adjustment among patients and partners: a randomized clinical trial. Nurs Res. 2008;57(3):199–213.18496106
170 Caljouw MA, Hogendorf-Burgers ME. GYNOTEL: telephone advice to gynaecological surgical patients after discharge. J Clin Nurs. 2010;19(23-24):3301–3306.20946445
171 Crane-Okada R, Freeman E, Kiger H, . Senior peer counseling by telephone for psychosocial support after breast cancer surgery: effects at six months. Oncol Nurs Forum. 2012;39(1):78–89.22201658
172 Damholdt MF, Mehlsen M, O’Toole MS, Andreasen RK, Pedersen AD, Zachariae R. Web-based cognitive training for breast cancer survivors with cognitive complaints-a randomized controlled trial. Psychooncology. 2016;25(11):1293–1300.26763774
173 Davison BJ, Degner LF. Feasibility of using a computer-assisted intervention to enhance the way women with breast cancer communicate with their physicians. Cancer Nurs. 2002;25(6):417–424.12464832
174 Ell K, Vourlekis B, Xie B, . Cancer treatment adherence among low-income women with breast or gynecologic cancer: a randomized controlled trial of patient navigation. Cancer. 2009;115(19):4606–4615.19551881
175 Gallagher R, McKinley S, Dracup K. Effects of a telephone counseling intervention on psychosocial adjustment in women following a cardiac event. Heart Lung. 2003;32(2):79–87.12734530
176 Gustafson DH, McTavish FM, Stengle W, . Use and Impact of eHealth System by Low-income Women With Breast Cancer. J Health Commun. 2005;10 Suppl 1:195–218.16377608
177 Hageman PA, Pullen CH, Hertzog M, Boeckner LS. Effectiveness of tailored lifestyle interventions, using web-based and print-mail, for reducing blood pressure among rural women with prehypertension: main results of the Wellness for Women: DASHing towards Health clinical trial. Int J Behav Nutr Phys Act. 2014;11:148.25480461
178 Hoyer BB, Toft GV, Debess J, Ramlau-Hansen CH. A nurse-led telephone session and quality of life after radiotherapy among women with breast cancer: a randomized trial. Open Nurs J. 2011;5:31–37.21660182
179 Kleiboer A, Sorbi M, van Silfhout M, . Short-term effectiveness of an online behavioral training in migraine self-management: A randomized controlled trial. Behav Res Ther. 2014;61:61–69.25133856
180 Kristjansdottir OB, Fors EA, Eide E, . A smartphone-based intervention with diaries and therapist feedback to reduce catastrophizing and increase functioning in women with chronic widespread pain. part 2: 11-month follow-up results of a randomized trial. J Med Internet Res. 2013;15(3):e72.23538392
181 Lin CH, Chiang SL, Heitkemper MM, . Effects of telephone-based motivational interviewing in lifestyle modification program on reducing metabolic risks in middle-aged and older women with metabolic syndrome: A randomized controlled trial. Int J Nurs Stud. 2016;60:12–23.27297365
182 Marcus AC, Garrett KM, Cella D, . Can telephone counseling post-treatment improve psychosocial outcomes among early stage breast cancer survivors? Psychooncology. 2010;19(9):923–932.19941285
183 Miller SM, Hui SK, Wen KY, . Tailored telephone counseling to improve adherence to follow-up regimens after an abnormal pap smear among minority, underserved women. Patient Educ Couns. 2013;93(3):488–495.24007767
184 Mishel MH, Germino BB, Gil KM, . Benefits from an uncertainty management intervention for African-American and Caucasian older long-term breast cancer survivors. Psychooncology. 2005;14(11):962–978.15712339
185 Pierce JP, Natarajan L, Caan BJ, . Influence of a diet very high in vegetables, fruit, and fiber and low in fat on prognosis following treatment for breast cancer: the Women’s Healthy Eating and Living (WHEL) randomized trial. Jama. 2007;298(3):289–298.17635889
186 Pierce JP, Newman VA, Natarajan L, . Telephone counseling helps maintain long-term adherence to a high-vegetable dietary pattern. J Nutr. 2007;137(10):2291–2296.17885013
187 Salonen P, Kellokumpu-Lehtinen PL, Tarkka MT, Koivisto AM, Kaunonen M. Changes in quality of life in patients with breast cancer. J Clin Nurs. 2011;20(1-2):255–266.21108675
188 Salonen P, Tarkka MT, Kellokumpu-Lehtinen PL, Astedt-Kurki P, Luukkaala T, Kaunonen M. Telephone intervention and quality of life in patients with breast cancer. Cancer Nurs. 2009;32(3):177–190; quiz 191-172.19295417
189 Sjostrom M, Umefjord G, Lindholm L, Samuelsson E. Cost-effectiveness of an Internet-based treatment program for stress urinary incontinence. Neurourol Urodyn. 2015;34(3):244–250.24347521
190 Sjostrom M, Umefjord G, Stenlund H, Carlbring P, Andersson G, Samuelsson E. Internet-based treatment of stress urinary incontinence: 1- and 2-year results of a randomized controlled trial with a focus on pelvic floor muscle training. BJU Int. 2015;116(6):955–964.25683075
191 Sjöström M, Umefjord G, Stenlund H, . Internet-based treatment of stress urinary incontinence: 1- and 2-year results of a randomized controlled trial with a focus on pelvic floor muscle training. BJU Int. 2015;116(6):955–964.25683075
192 Skelly AH, Carlson J, Leeman J, Soward A, Burns D. Controlled trial of nursing interventions to improve health outcomes of older African American women with type 2 diabetes. Nurs Res. 2009;58(6):410–418.19851122
193 Stuifbergen AK, Blozis SA, Becker H, . A randomized controlled trial of a wellness intervention for women with fibromyalgia syndrome. Clin Rehabil. 2010;24(4):305–318.20360151
194 Wenzel L, Osann K, Hsieh S, Tucker JA, Monk BJ, Nelson EL. Psychosocial telephone counseling for survivors of cervical cancer: results of a randomized biobehavioral trial. J Clin Oncol. 2015;33(10):1171–1179.25713429
195 Ziller V, Kyvernitakis I, Knoll D, Storch A, Hars O, Hadji P. Influence of a patient information program on adherence and persistence with an aromatase inhibitor in breast cancer treatment--the COMPAS study. BMC Cancer. 2013;13:407.24006873
196 Rock CL, Thomson C, Caan BJ, . Reduction in fat intake is not associated with weight loss in most women after breast cancer diagnosis: evidence from a randomized controlled trial. Cancer. 2001;91(1):25–34.11148556
197 Parsapure R, Rahimiforushani A, Majlessi F, . Impact of health-promoting educational intervention on lifestyle (Nutrition behaviors, physical activity and mental health) related to vaginal health among reproductive-aged women with vaginitis. Iranian Red Crescent Medical Journal. 2016;18:10 Article Number: e37698.
198 Ayiasi RM, Muhumuza C, Bukenya J, Orach CG. The effect of prenatal counselling on postpartum family planning use among early postpartum women in Masindi and Kiryandongo districts, Uganda. Pan Afr Med J. 2015;21:138.26327975
199 Berenson AB, Rahman M. A randomized controlled study of two educational interventions on adherence with oral contraceptives and condoms. Contraception. 2012;86(6):716–724.22840278
200 Gerris J, Delvigne A, Dhont N, . Self-operated endovaginal telemonitoring versus traditional monitoring of ovarian stimulation in assisted reproduction: an RCT. Hum Reprod. 2014;29(9):1941–1948.24993931
201 Hameed W, Azmat SK, Ali M, . Comparing Effectiveness of Active and Passive Client Follow-Up Approaches in Sustaining the Continued Use of Long Acting Reversible Contraceptives (LARC) in Rural Punjab: A Multicentre, Non-Inferiority Trial. PLoS One. 2016;11(9):e0160683.27584088
202 Ngoc NT, Bracken H, Blum J, . Acceptability and feasibility of phone follow-up after early medical abortion in Vietnam: a randomized controlled trial. Obstet Gynecol. 2014;123(1):88–95.24463668
203 Paul M, Iyengar K, Essén B, . Acceptability of home-assessment post medical abortion and medical abortion in a low-resource setting in Rajasthan, India. Secondary outcome analysis of a non-inferiority randomized controlled trial. PLoS ONE. 2015;10:9 Article Number: e0133354.
204 Schover LR, Rhodes MM, Baum G, . Sisters Peer Counseling in Reproductive Issues After Treatment (SPIRIT): a peer counseling program to improve reproductive health among African American breast cancer survivors. Cancer. 2011;117(21):4983–4992.21495025
205 Smith C, Ngo TD, Gold J, . Effect of a mobile phone-based intervention on post-abortion contraception: a randomized controlled trial in Cambodia. Bull World Health Organ. 2015;93(12):842–850a.26668436
206 Sridhar A, Chen A, Forbes ER, Glik D. Mobile application for information on reversible contraception: a randomized controlled trial. Am J Obstet Gynecol. 2015;212(6):774.e771–777.25582097
207 Tsur L, Kozer E, Berkovitch M. The effect of drug consultation center guidance on contraceptive use among women using isotretinoin: a randomized, controlled study. J Womens Health (Larchmt). 2008;17(4):579–584.18447762
208 Skiadas CC, Terry K, De Pari M, . Does emotional support during the luteal phase decrease the stress of in vitro fertilization? Fertil Steril. 2011;96(6):1467–1472.22000914
209 Bloom JR, Stewart SL, Chang S, You M. Effects of a telephone counseling intervention on sisters of young women with breast cancer. Prev Med. 2006;43(5):379–384.16916540
210 Chang Y, Near AM, Butler KM, . Economic Evaluation Alongside a Clinical Trial of Telephone Versus In-Person Genetic Counseling for BRCA1/2 Mutations in Geographically Underserved Areas. J Oncol Pract. 2016;12(1):59, e51–13.26759468
211 Jenkins J, Calzone KA, Dimond E, . Randomized comparison of phone versus in-person BRCA1/2 predisposition genetic test result disclosure counseling. Genet Med. 2007;9(8):487–495.17700386
212 Kinney AY, Butler KM, Schwartz MD, . Expanding access to BRCA1/2 genetic counseling with telephone delivery: a cluster randomized trial. J Natl Cancer Inst. 2014;106(12).
213 Kinney AY, Steffen LE, Brumbach BH, . Randomized Noninferiority Trial of Telephone Delivery of BRCA1/2 Genetic Counseling Compared With In-Person Counseling: 1-Year Follow-Up. J Clin Oncol. 2016;34(24):2914–2924.27325848
214 Schwartz MD, Valdimarsdottir HB, Peshkin BN, . Randomized noninferiority trial of telephone versus in-person genetic counseling for hereditary breast and ovarian cancer. J Clin Oncol. 2014;32(7):618–626.24449235
215 White VM, Young MA, Farrelly A, . Randomized controlled trial of a telephone-based peer-support program for women carrying a BRCA1 or BRCA2 mutation: impact on psychological distress. J Clin Oncol. 2014;32(36):4073–4080.25403211
216 Beaver K, Tysver-Robinson D, Campbell M, . Comparing hospital and telephone follow-up after treatment for breast cancer: randomised equivalence trial. BMJ. 2009;338:a3147.19147478
217 de Bie RP, Massuger LF, Lenselink CH, Derksen YH, Prins JB, Bekkers RL. The role of individually targeted information to reduce anxiety before colposcopy: a randomised controlled trial. BJOG. 2011;118(8):945–950.21658194
218 Gotay CC, Moinpour CM, Unger JM, . Impact of a peer-delivered telephone intervention for women experiencing a breast cancer recurrence. J Clin Oncol. 2007;25(15):2093–2099.17513815
219 Ireys HT, Chernoff R, DeVet KA, Kim Y. Maternal outcomes of a randomized controlled trial of a community-based support program for families of children with chronic illnesses. Arch Pediatr Adolesc Med. 2001;155(7):771–777.11434842
220 Tiwari A, Fong DY, Yuen KH, . Effect of an advocacy intervention on mental health in Chinese women survivors of intimate partner violence: a randomized controlled trial. Jama. 2010;304(5):536–543.20682933
221 Morland LA, Mackintosh MA, Rosen CS, . Telemedicine versus In-Person Delivery of Cognitive Processing Therapy for Women with Posttraumatic Stress Disorder: A Randomized Noninferiority Trial. Depress Anxiety. 2015;32(11):811–820.26243685
222 McFarlane J, Malecha A, Gist J, . Increasing the safety-promoting behaviors of abused women. Am J Nurs. 2004;104(3):40–50; quiz 50-41.
223 Saftlas AF, Harland KK, Wallis AB, Cavanaugh J, Dickey P, Peek-Asa C. Motivational interviewing and intimate partner violence: a randomized trial. Ann Epidemiol. 2014;24(2):144–150.24252714
224 Stevens J, Scribano PV, Marshall J, Nadkarni R, Hayes J, Kelleher KJ. A Trial of Telephone Support Services to Prevent Further Intimate Partner Violence. Violence Against Women. 2015;21(12):1528–1547.26223696
225 Tiwari A, Yuk H, Pang P, . Telephone intervention to improve the mental health of community-dwelling women abused by their intimate partners: a randomised controlled trial. Hong Kong Med J. 2012;18 Suppl 6:14–17.23249846
226 Abrahams N, Jewkes R, Lombard C, Mathews S, Campbell J, Meel B. Impact of telephonic psycho-social support on adherence to post-exposure prophylaxis (PEP) after rape. AIDS Care. 2010;22(10):1173–1181.20640949
227 van-Velthoven MH, Tudor Car L, Gentry S, Car J. Telephone delivered interventions for preventing HIV infection in HIV-negative persons. Cochrane Database Syst Rev. 2013(5):Cd009190.23728688
228 Bandura A. Social Learning Theory. Englewood Cliffs, NJ: Prentice-Hall; 1977.
229 Prochaska JO, DiClemente CC. Stages and processes of self-change of smoking: toward an integrative model of change. J Consult Clin Psychol. 1983;51(3):390–395.6863699
230 Pender NJ, Murdaugh CL, Parsons MA. Health Promotion in Nursing Practice (7th Edition). Pearson Education Inc, 2015.
231 Dahl J, Wilson KG, Luciano C, Hayes SC. Acceptance and Commitment Therapy for Chronic Pain. Reno, NV: Context Press, 2005.
232 Bandura A. Health promotion by social cognitive means. Health Educ Behav. 2004;31(2):143–164.15090118
233 Rosenstock IM. Historical Origins of the Health Belief Model. Health Educ Monogr. 1974;2(4):328–335.
234 Leventhal H, Cameron L. Behavioral theories and the problem of compliance. Vol 101987.
235 Cohen S, Mermelstein R, Kamarck T, Hoberman H. Social Support: Theory, Research and Applications 1985.
236 Dutton M. Empowering and healing the battered women: a model for assessment and intervention. New York: Springer Publishing Co; 1992.
237 Cohen S. Psychosocial models of the role of social support in the etiology of physical disease. Health Psychol. 1988;7(3):269–297.3289916
238 Walker L. The Battered Woman. 1st ed: Harper & Rowe; 1979.
239 Curnow SA. The Open Window Phase: helpseeking and reality behaviors by battered women. Appl Nurs Res. 1997;10(3):128–135.9274065
240 Bean-Mayberry BA, Chang CC, McNeil MA, Scholle SH. Ensuring high-quality primary care for women: predictors of success. Womens Health Issues. 2006;16(1):22–29.16487921
241 Kimerling R, Bastian LA, Bean-Mayberry BA, . Patient-centered mental health care for female veterans. Psychiatr Serv. 2015;66(2):155–162.25642611
242 Misra DP, Giurgescu C. Effects of Post-traumatic Stress Disorder on Pregnancy among US Military Veterans: Lessons for Research on Stress and Racial Disparities. Paediatr Perinat Epidemiol. 2017;31(3):195–197.28444992
243 Shivakumar G, Anderson EH, Suris AM. Managing posttraumatic stress disorder and major depression in women veterans during the perinatal period. J Womens Health (Larchmt). 2015;24(1):18–22.25560190
244 Shaw JG, Asch SM, Kimerling R, Frayne SM, Shaw KA, Phibbs CS. Posttraumatic stress disorder and risk of spontaneous preterm birth. Obstet Gynecol. 2014;124(6):1111–1119.25415162
245 Shaw JG, Asch SM, Katon JG, . Post-traumatic Stress Disorder and Antepartum Complications: a Novel Risk Factor for Gestational Diabetes and Preeclampsia. Paediatr Perinat Epidemiol. 2017;31(3):185–194.28328031
246 Katon JG, Lewis L, Hercinovic S, McNab A, Fortney J, Rose SM. Improving Perinatal Mental Health Care for Women Veterans: Description of a Quality Improvement Program. Matern Child Health J. 2017;21(8):1598–1605.28168592
247 U.S. Department of Veterans Affairs. Examining Patterns of Mental Health Utilization Among Pregnant and Postpartum Veterans. Video presented by Kristin Mattocks, PhD, MPH. Available at: https://www.hsrd.research.va.gov/meetings/2017/streamed_sessions/Pregnant_postpartum.cfm. Accessed November 8, 2017.
248 Yano EM. A partnered research initiative to accelerate implementation of comprehensive care for women veterans: the VA women’s health CREATE. Med Care. 2015;53(4 Suppl 1):S10–14.25767962
249 Fox AB, Hamilton AB, Frayne SM, . Effectiveness of an Evidence-Based Quality Improvement Approach to Cultural Competence Training: The Veterans Affairs’ “Caring for Women Veterans” Program. J Contin Educ Health Prof. 2016;36(2):96–103.27262152
250 Frayne SM, Carney DV, Bastian L, . The VA Women’s Health Practice-Based Research Network: amplifying women veterans’ voices in VA research. J Gen Intern Med. 2013;28 Suppl 2:S504–509.23807057
251 Goldstein KM, Vogt D, Hamilton A, . Practice-based research networks add value to evidence-based quality improvement. Healthc (Amst). 2017.