# Summary and Discussion

Telehealth can be an essential tool to deliver the right intervention to the right patient at the right time by improving access to care and facilitating the secure sharing of health information. VA has been on the forefront of implementing telehealth solutions as a way to extend care to key populations of interest or to overcome barriers to receiving timely and high-quality care.^3,4^ Women Veterans are one such key population that could benefit from the flexibility and access afforded by telehealth because they are geographically dispersed within the Veterans Health Administration (VHA) and have gender-specific care needs. Further, women Veterans may be particularly amenable to telehealth as an alternative form of health care because of more frequent interactions with providers compared to their male counterparts and an expressed preference for telephone contacts with their care providers.^8^ Given the multiple modalities of telehealth that could be targeted within the VHA to address the care needs of women Veterans, it is imperative to understand the existing literature supporting this approach to care delivery.

The goal of this report was to characterize the quantity, distribution, and characteristics of evidence for the use of telehealth services designed specifically for women. To our knowledge, this is the first attempt to map this literature base. We identified 209 reports of primary studies and 2 systematic reviews. These included 81 primary studies and 1 SR pertaining to maternal care, 56 to prevention, 43 to disease management, 11 to family planning, 7 to assessment of women at high-risk for breast cancer, 6 to mental health, and 5 primary studies and 1 SR to intimate partner violence (IPV). When looking across the 7 focused areas of research, the majority of studies identified recruited 250 or fewer participants (Figure 13 and Appendix C).

Age distributions in the identified literature tracked with population distributions of women potentially impacted with identified health conditions. For example, all studies of breast cancer high-risk management were among women with mean ages in the 40s and 50s, and maternal care studies were focused on women in their 20s and 30s. Yet, there was an overall trend of limited telehealth studies intervening on the health issues of women aged 60 years and older across the identified reports on prevention, disease management, mental health, and IPV. Further, when mapping the race and ethnic composition of included studies, we found that very few studies reported the race and ethnic distribution of women included in these studies. For the studies that did provide data on race distribution, most included populations that were predominantly white (Figure 13).

Figure 13 Study Characteristics by Focused Areas of Research

When mapping the evidence on the key characteristics of telehealth centrality, modality, and focus of the treatment dyad, clear patterns emerged (Figure 14). First, among the identified literature, telehealth technologies were rated to be the only or primary (ie, central) mode of intervention delivery across the majority of studies. Next, across all areas of research, telephone was the dominant modality to deliver intervention content. Notably, among the literature with the smallest footprint (ie, high-risk breast cancer assessment, mental health, IPV), we identified no studies that used telehealth technologies beyond the telephone. While the dominant use of the telephone likely reflects the longevity of experience with care delivery using this modality (eg, telephone counseling), there is a lack of evidence on alternative telehealth modalities such as mobile-based apps or SMS/texting. In developing these approaches, VA will be well-suited to contribute to the growing literature around this health care innovation. Last, most studies used telehealth technologies to facilitate communication between patients and health care team members. Only 1 prevention-focused study used telehealth to communicate from health care provider-to-provider.

Figure 14 Intervention Components by Focused Areas of Research

When mapping the type of interventionist used in telehealth approaches for women, very few were physicians or advanced practice providers (eg, nurse practitioners, physician assistants) (Figure 15). Instead, these interventions were mostly supported by a diverse variety of credentialed (eg, registered nurses, behavioral health specialists) and noncredentialed positions (eg, health educators, peer or lay health workers)—thus involving additional health care team members in the delivery of non-face-to-face care and expanding the resources of a traditional care team. The majority of the identified studies were limited in their duration and did not extend beyond 12 weeks. The only exception was among studies focused on prevention; the majority of these were 25 weeks or more.

Figure 15 Interventionist and Length of Intervention by Focused Areas of Research

When mapping the setting of telehealth interventions designed for women, the overwhelming majority of studies were conducted in countries categorized as high income by the Word Bank. The only exception to this was in the area of family planning, where half the studies were conducted in middle- and low-income countries. When looking across the literature, most studies recruited from outpatient clinics (including specialty outpatient clinics), followed by community-based recruiting (Figure 16).

Figure 16 Study Setting by Focused Areas of Research

## Implications of Findings

Women Veterans have multiple personal and structural barriers to seeking care within the VHA. First, women have multiple competing priorities that can make it difficult for them to seek and obtain the health care they need. Further, many VA sites have large catchment areas, and women Veterans may be dispersed across these catchment areas. For example, the growing number of pregnancies within the women Veteran population are geographically dispersed across the country with relatively small numbers at even larger VA sites. While the proportion of women using the VA for health care is growing, women Veterans still comprise a large minority of patients served compared with their male counterparts. Also, women Veterans have a need and preference for gender-specific care that is sensitized to their particular needs as Veterans.^240,241^ Recent studies of pregnant Veterans note challenges related to mental health comorbidities and increased risk of complication.^13,242–246^ Thus, there are pockets of women Veterans in need of specialized clinical care that lack the population density to support services at individual VA health care centers.

The expansion and optimization of telehealth directly aligns with VHA top priorities. Namely, the VHA is committed to improving the timeliness of health care delivery, and telehealth is seen as a key solution to advance this priority. Telehealth offers a potentially ideal approach to deliver targeted support to women Veterans in a manner that is convenient to the patient and does not require traveling long distances. From a provider and system level, telehealth provides additional tools to aid the facilitation of continuity of care and transitions of care (eg, post-acute care) and can be a powerful tool for population health management. In this evidence map, we illustrate the areas in which telehealth for women have been examined. There is a significant literature that has tested telehealth as a strategy to support maternal care, which may be of particular interest to VA as they seek to expand their maternal care coordination efforts^13^ due to the growing number of women of childbearing age who are dispersed throughout the VHA.

We also identified significant bodies of literature related to prevention and disease management using telehealth interventions designed specifically for women. Integrating telehealth in these areas, as the VA in currently implementing, can allow for a realignment of health care resources. We identified a wide range of interventionists who delivered care. Thus, telehealth may also be a strategy that allows the integration of additional, nontraditional personnel resources to the health care team. Providing patient access to other health care team members frees up physicians and advanced practice providers to spend more time on high-risk, complex patients. Yet the dearth of provider- and system-level outcomes measured by existing literature limits our ability to explore the feasibility and sustainability of telehealth interventions for women. For interventions that involve providers (eg, provider-to-patient or provider-to-provider), it is important to understand how strategies are received by the providers, if providers perceive these strategies as beneficial to optimize the efficiency and quality of clinical decision-making, and if it improves system-level outcomes like access to high-quality care and retention of personnel. Last, as technology evolves and becomes further integrated into clinical practice, it will be important to understand provider perspectives in order to customize strategies to meet the needs of providers and to optimize stakeholder buy-in during future implementation efforts.

## Limitations

Evidence mapping is an evolving methodology, without well-defined best practices. While we conducted this review with high scientific rigor, our evidence map has limitations. First, identifying and mapping the body of literature on telehealth strategies for women was challenging. There are multiple definitions of telehealth and each one has implications for searching and identifying the literature base. In collaboration with our stakeholders, we developed an operational definition that was most relevant to the VA care context. Thus, other ways of operationalizing telehealth may produce different results. Similarly, we could have included studies of telehealth that included mixed-gender populations but which conducted sexor gender-based analysis. While we made this choice intentionally, we acknowledge that we may have missed some relevant findings. Further, in collaboration with our stakeholders and panel of technical experts, we only included study designs set forth by the Cochrane Effective Practice and Organization of Care (EPOC) Group^16^—criteria developed to capture both randomized and nonrandomized study designs best suited to assess the effects of health system interventions like telehealth. Thus, we may have excluded other relevant studies that used observational designs. We chose EPOC designs because our research focus was on mapping the literature that assessed the effectiveness of telehealth strategies for women. In order to focus on studies large enough to provide meaningful findings, we limited our inclusion criteria to those studies that included at least 100 patients. While this would have allowed trials for which the unit of randomization was providers or systems, requiring a minimum number of patients may have excluded studies with relevant findings. Due to the size and scope of this review, we did not conduct dual review or abstraction of all studies. However, we conducted targeted dual review and over-reading and monitored those targeted reviews for acceptable levels of agreement. Further, we classified studies into broad, focused areas of research, potentially limiting interpretation of results. However, we further classified the largest identified literature, maternal health, by subcategories to aid the interpretation of this key body of literature. Also, because this study was an evidence map and the purpose of the study was to characterize and visualize a broad literature base, we did not provide summary estimates of effects. We also did not assess the quality of the literature base. To mitigate this limitation, we only included randomized and nonrandomized study designs of higher methodological rigor as outlined by the EPOC criteria.^16^ It is possible that this decision excluded some provider- and system-focused studies that may be more likely to use other designs.

## Research Gaps/Future Research

A key use of these maps is to inform decisions about where more primary research is needed. The evidence maps in this report serve as a broad visualization of the field of telehealth interventions for women and a foundation for future research in this area (Appendix C). Beyond maternal health care, we identified a relatively small number of telehealth studies that addressed other gender-specific needs of women Veterans and underscore areas that warrant further exploration such as family planning, IPV, homelessness, pain management, and high-risk breast cancer assessment. Further, beyond postpartum depression, few studies used telehealth interventions to address the mental health needs of women. For example, many pregnant women Veterans have comorbid mental health conditions and may disconnect from their mental health provider during pregnancy as they transition to a community obstetric provider.^247^ Assessing telehealth strategies designed for this population may provide an important tool to enhance continuity of care. The wealth of existing literature about telehealth for maternity care could inform the development of future telehealth interventions for this population within VA.

We also found relatively few studies among older women, or studies conducted with racially or ethnically diverse populations. So, there is a need to test telehealth strategies in more diverse patient populations and contexts. We also identified a dearth of studies focused on strategies to enhance provider-to-provider communication for women’s health conditions. Such studies are essential to assess the impact of telehealth interventions focused on gender-specific care. Further, telephone was by far the most commonly studied telehealth modality and newer approaches such as mobile health technologies were underrepresented. This gap underscores the need to study how best to use evolving technology that can address the needs of women. As noted, we identified a relatively small literature base that assesses provider and system outcomes. There is a need for research on the extent to which telehealth improves provider and system outcomes related to provider satisfaction and retention and patient access to care.

The brief duration of many interventions included in this review is a notable limitation of the current state of the evidence on telehealth interventions for women. One of the most promising aspects of telehealth for making large improvements in public health is the potential for such interventions to extend treatment over time by using interventions that have relatively low cost for the health care system. Chronic medical and mental health conditions often require frequent, long-term follow up to address symptom exacerbations and maintain treatment gains. This could be accomplished by utilizing telehealth interventions to increase the durability of treatment over time and reduce the frequency of high-cost clinic visits. There is a need for more research using telehealth to improve long-term health outcomes.

While we found very few telehealth studies based within VA, the nature of VA as a large and diverse health care system that has been a national leader in developing and implementing telehealth modalities creates many opportunities to pursue multisite trials to address some of the gaps in the body of literature described in this report. Of relevance, there have been many multisite VA studies that demonstrate the capacity for this type of research.^248,249^ In particular, the VA Women’s Health Practice-Based Research Network is an active research and quality improvement infrastructure designed to support multisite studies that seek to recruit sufficient numbers of women to support adequately powered trials.^250,251^

## Conclusions

Telehealth can be a powerful tool to enhance access, quality, and satisfaction with health care. Due to geographic spread and gender-specific needs, women Veterans are a key population that could benefit from expanding care via telehealth modalities. This review mapped the current landscape of the published literature on telehealth strategies designed to address women and their health care needs. We identified 209 primary reports and 2 systematic reviews addressing telehealth interventions for women. Our findings highlight some notable gaps in the literature, including the need for more exploration in the areas of mental health, pain management, IPV, and family planning. We note the need to explore the testing of alternative telehealth modalities such as texting and videoconferencing and the need to test these strategies in more diverse populations of women. Key to VA, we also note the need to implement studies that assess the impact of telehealth on provider- and system-level outcomes. Only after such studies have been conducted can we assess the full promise of telehealth strategies to optimize the care and well-being of women Veterans across the VA health care system.