# Methods

## Topic Development

In consultation with our stakeholders, and in keeping with the principles of evidence mapping,^14^ our intent was to provide high-level information about a broad question rather than detailed information on a narrow set of questions. Also in keeping with evidence mapping, our intent was to describe the landscape of high-quality literature in the field of telehealth for women that would support effectiveness determinations rather than a focused analysis of the effectiveness of any particular telehealth approach. Thus the key question (KQ) for this report was:

KQ: What are the quantity, distribution, and characteristics of evidence assessing the effectiveness of telehealth services designed specifically for women?

Of note, our inclusion of the language “designed specifically for women” was done purposely and after significant deliberation for the following reasons. This language was put forth by our operations partners as being of particular interest, and in collaboration with our partners we operationalized it to mean interventions designed for a female-predominant condition or interventions that affected both sexes but are customized for, and assessed among, women. In a previous ESP project, we conducted an evidence map assessing sex and gender-based analysis in trials of depression, diabetes, and chronic pain.^15^ In that evidence map, we found that only 10% of eligible reviews including analyses of sex effects. Thus, we did not expect that the inclusion of telehealth interventions in mixed-gender populations would offer a significant yield of relevant sex-effect subanalyses.

The term telehealth can be used to encompass a wide variety of strategies and approaches in the context of health care. For the purposes of this project, we operationalized telehealth broadly based on input from our stakeholders, our technical expert panel, and definitions used in the literature and by government and other organizations. Specifically, we considered telehealth to mean any bidirectional technology or tactic used to synchronously or asynchronously transmit clinical information across a distance between patients and members of the medical/mental health care team or provider-to-provider interactions for the purpose of diagnosis, consultation, treatment, and/or prevention. Examples of telehealth technologies are telephone, short message service (SMS)/text messaging, electronic consultation, video conferencing, and interactive voice response systems. Based on the interests of our stakeholders, we also explicitly included telegynecology, tele-colposcopy, tele-mental health, tele-pharmacy, tele-care coordination, tele-primary care, and tele-wellness.

We followed a standard protocol for this review. Each step was pilot-tested to train and calibrate study investigators. The PROSPERO registration number is CRD42017065965.

## Search Strategy

In collaboration with an expert reference librarian, we searched MEDLINE® (via PubMed®) and Embase® to identify relevant articles and systematic reviews (SRs) published between inception and December 29, 2016. Because our stakeholders were interested in the literature that assessed the effectiveness of telehealth strategies, our search strategy was informed by the Cochrane Effective Practice and Organization of Care (EPOC) Group^16^ – criteria developed to capture both randomized and nonrandomized study designs with prospective data collection best suited to assess the effects of health system interventions like telehealth. We used a combination of medical subject headings (MeSH), keywords, and selected free-text terms for women’s health and telemedicine (Appendix A). All citations were imported into 2 electronic databases (for referencing, EndNote® Version X7, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## Study Selection

Using prespecified inclusion/exclusion criteria (Table 1), 2 reviewers independently evaluated titles and abstracts to identify potentially eligible primary studies and SRs. Studies then advanced to the full-text review phase. To be eligible at the full-text review stage, studies had to meet all eligibility criteria. If we were unable to assess an eligibility criterion due to missing information, the study was excluded. We chose to restrict eligible studies to those that included at least 100 patient participants (regardless of whether the unit of randomization was at the provider or system level) in order to concentrate our efforts on those studies with sufficient sample sizes to provide useful effectiveness information.

Due to the large volume of primary studies, we assessed the feasibly of a conducting single review at the full-text article stage. To test the feasibility of single review, we conducted a pilot to assess the concordance of reviewers at the full-text review phase. This pilot produced an inter-rater reliability of 87%, which we deemed as an acceptable level to proceed with single full-text review. To assess the rigor of the single full-text review process, we conducted an ongoing evaluation of single review by conducting a random dual screening by another senior investigator (JMG, KMG). An interim examination of the random sample demonstrated acceptable concordance on excluded studies but poor concordance on included studies. Thus all studies categorized as included by single review went through a dual full-text review by senior investigators (KMG, JMG).

The SRs were examined separately by 2 team members. Disagreements were resolved by consensus between the 2 investigators or by a third investigator. Articles meeting all eligibility criteria were included for data abstraction.

Table 1 Study Eligibility Criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Adult biological or transgender women only | - Children; - Men
Intervention | Eligible telehealth interventions must meet the following 4 criteria:; 1. Intended for any of the following categories of conditions:; - [underlined: Women-specific conditions:]; ○ Obstetric; ○ Gynecologic; - [underlined: Conditions that predominantly affect women]:; ○ Migraine; ○ Fibromyalgia; ○ Breast cancer (eg, risk assessments like the Gail model and genetic counseling; management decisionmaking for women at high risk for breast cancer such as counseling for pharmacoprophylatic treatment; behavioral counseling for survivors focused on pain, diet, weight management); ○ Intimate partner or sexual violence, military sexual trauma, or domestic violence; - [underlined: Gender nonspecific conditions, but intervention is designed specifically for women]; 2. Use technologies and tactics (eg, secure messaging, text messaging,^a^ e-consultation, video-conferencing, interactive voice response) to deliver health care services for the purpose of diagnosis, consultation, treatment, and/or prevention, including tele-gynecology, telecolposcopy, tele-mental health, tele-pharmacy, tele-care coordination, tele-primary care, telewellness; 3. Involve transmission of clinical information via a telecommunication technology between patients and members of the medical/mental health care team^b^ or provider-to-provider interactions who are at a distance; 4. Include bidirectional synchronous or asynchronous communication | - Static portals without an interactive component; - One-way communication (eg, automatic reminder telephone calls); - Use of technologies and tactics (eg, secure messaging, text messaging^a^, e-consultation, videoconferencing, interactive voice response) for data collection or recruitment only; - Studies promoting breast cancer screening for average risk women will be excluded; - Interventions whose only telehealth component promotes a hotline or offers ad hoc calls from the participant without specifically requiring them as part of the intervention protocol
Comparator | Any (requires an active or inactive control) | No comparator
Outcomes | - Patient health outcomes, condition-specific:; ○ Readiness/motivation to change; ○ Access to care (eg, no-show rates); ○ Patient satisfaction; ○ Treatment adherence; ○ Patient engagement; - Provider-level outcomes; - System-level outcomes | - Outcomes on enhancing data collection only; - Outcomes on enhancing recruitment only
Timing | Any duration of follow-up | None
Setting | - Any clinical setting; - Any country (assessed country and categorized according to low/middle/high income status) | None
Study design | - EPOC criteria studies that have prospective data collection:; ○ Randomized controlled trials (RCTs); ○ Nonrandomized controlled studies; ○ Controlled before-after studies; ○ Interrupted time-series or repeated-measures studies; - Relevant systematic reviews or patient-level meta-analyses:; ○ Must have search strategy, eligibility criteria, and analysis/synthesis plan; ○ Must be a systematic review of telehealth interventions for women; ○ Must have at least 50% of the included articles be relevant to the topic (women’s telehealth interventions) | - Self-identified pilot studies; - Studies of small sample sizes (n<100 patient participants); - Not a clinical study (eg, editorial, nonsystematic review, letter to the editor); - Uncontrolled clinical study; - Qualitative studies; - Prospective and retrospective observational studies; - Clinical guidelines; - Systematic reviews of telehealth that includes both sexes
Publication type | - English language studies only; - Peer-reviewed articles | - Non-English articles; - Abstracts only

a Text messaging systems that are interactive based on a predetermined algorithm are included even if there is not real-time human participation on the clinical end of the interaction.

b Team member can include those who are without formal medical training (eg, health coaches, nonskilled health care workers).

## Data Abstraction

Data from primary studies were abstracted into a customized DistillerSR database by 1 reviewer, and a random sample of 10% were overread by 1 of 3 senior reviewers. Any disagreements were resolved by consensus between the senior reviewers or arbitrated by the study team. Data from SRs were abstracted into an Excel database and overread by senior reviewers. Disagreements were resolved by consensus between the reviewers.

Data elements included descriptors to characterize the type of study, intervention, comparator, outcomes reported, and study population. Additional elements for abstraction were requested from and provided by the technical expert panel and stakeholders. The telehealth interventions were further categorized by direction (eg, provider to patient), primary telehealth modality, and intervention timing (synchronous or asynchronous).

We also evaluated studies based on the centrality of the telehealth portion of the intervention as follows:

- Telehealth as a central component: Telehealth technologies (eg, text messaging, mobile applications, telephone) were the [underlined: primary] mode of intervention delivery; if the intervention contained multiple components, the non-telehealth components (eg, written materials or in-person contact) had to play a minor role relaying intervention content, impacting outcomes, or delivering health care.
- Telehealth as a non-central component: Telehealth technologies were [underlined: ancillary] to a suite of other intervention strategies. Most of the health care services and information content were conveyed via non-telehealth technologies (eg, face-to-face visits), and telehealth technologies were not a central design feature of the intervention.

## Quality Assessment

Because this was an evidence mapping study, we did not collect data to assess the quality of individual studies. A formal assessment of individual study methodological rigor was beyond the scope of a mapping project.

## Data Synthesis

We mapped the literature by the focused areas of research that emerged from our search – informed by both the interests of our stakeholders and organization of clinical care. The results are ordered from largest to smallest number of identified studies as follows: (1) maternal health, (2) prevention, (3) disease management, (4) family planning, (5) high-risk breast cancer assessment, (6) mental health, and (7) intimate partner violence (IPV). In some instances, study topics could have been categorized into more than a single area of research (eg, mental health care for pregnant women). In such instances, we categorized by the affected population (eg, maternal care for any intervention with pregnant women) and not by the target of the intervention (eg, improving mental health). Further, we identified 18 studies with more than 1 active telehealth arm.^17–34^ For these studies, we collapsed across conditions so that each study is represented only 1 time in graphical depictions of the data. We summarize the data narratively and include tabular and graphical formats to convey key features of the literature. These included demographics; recruitment site; intervention components, interventionist and length of intervention; type of outcomes (ie, patient-, provider-, system-level).

## Peer Review

A draft version of this report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is in Appendix B.