# Introduction

Telehealth is an important mechanism for delivering patient-centered health care outside the time and location restrictions of a traditional face-to-face medical encounter. According to the US Health Resources & Services Administration, telehealth is defined as “the use of electronic information and telecommunication technologies to support and promote long-distance clinical health care, patient and professional health-related education, public health and health administration.”^1^ Telehealth encompasses a variety of technologies and approaches to connect individual patients to health care resources with the goal of improving personalization, efficiency, access to care, and secure sharing of health information. Nationally, telehealth strategies have flourished due to an increased emphasis on the efficiency of health care delivery in recent health policies.^2^ Within VA, telehealth and advanced health information technology has long been an area of innovation.^3,4^ VA supports the use of telehealth^5,6^ and has experience with specific modalities such as mobile health applications (mHealth), clinical videoconferencing between patient and care providers, and asynchronous telehealth methods such as store-and-forward clinical information or home self-monitoring with data transmission via phone lines.^7^ Such technology-based strategies are appealing for VA as they accommodate a geographically diverse Veteran population while providing patient-centered care.

One population within the Veterans Health Administration (VHA) that benefits from the flexibility and personalized delivery approach offered by telehealth modalities is women Veterans. Women Veterans are the fastest-growing population receiving care in the VHA, with the total number of women doubling between fiscal years 2003 and 2012.^8^ Despite this growth, the absolute number of women at any particular VA health care system or community-based outpatient clinic (CBOC) can be quite small. This lack of density creates challenges to providing high-quality, efficient, and cost-effective gender-specific care for women within the VHA. Further, at least one-quarter of women Veterans reside in rural areas,^8^ and women Veterans living in rural areas are more likely to depend on the VA as their primary health care compared to urban-dwelling women.^9^ For women living in rural areas, affordability and transportation are significant issues when making health care choices.^9^ In particular, women Veterans have expressed a preference for receiving specialty health care services closer to home,^10^ which is challenging for those living in rural areas. Even women living in urban areas face barriers to obtaining timely health care, including difficulty obtaining time off from work.^9^ Faced with the mandate to provide quality health care to the growing and complex population of women Veterans, the VHA has prioritized improving the quality of health care for women Veterans.^11^

Telehealth may be a good fit for addressing the needs of women Veterans because alternate forms of health care communication are already in use by this population. Compared with men, women Veterans are more likely to contact their health care team by telephone (63% vs 55%) and make a higher number of contacts via phone (4.6 vs 4.2 average encounters by phone).^8^ Women use other forms of telehealth (eg, video conferencing, home telehealth, and store and forward) at similar rates as men.^8^ Examples of gender-specific VA telehealth endeavors include remote consultations for gynecology and telephone-based maternity care coordination.^12,13^ By overcoming the challenges of low-density and geographic dispersion, technology-based communication offers innovative ways to deliver high-quality, gender-specific health care to women Veterans in a modality that is well-suited to this population.

This report’s objective is to describe the current landscape of telehealth interventions that have been designed specifically for women.