# APPENDIX D Primary Outcomes Table

Primary outcome | Maternal health (n=81) | Prevention (n=56) | Disease management (n=43) | Family planning (n=11) | High-risk breast cancer assessment (n=7) | Mental health (n=6) | Intimate partner violence (n=5)
Patient-level Outcomes
Breast feeding | 13
Cancer screening | | 12 | 1
Psychological and mental health assessment | 14 | 3 | 4 | 2 | 3 | 6 | 2
Physical health assessment | 1 | 0 | 9 | 2
Cognitive function | | | 1
Contraceptive use | | | | 2
Dietary change | 1 | 3 | 1
Immunization | 1
Infant development | 1
Intimate partner violence | | | | | | | 2
Medication adherence | | | 1 | 4 | | | 1
Patient knowledge | | | 1
Patient satisfaction | | 1 | | 1 | 1
Physical activity | | 10
Pregnancy outcomes | 12
Quality of life | | 3 | 13
Shared decision making | 1 | | 1
Smoking cessation | 7 | 9
Social support | 1 | 1
Substance use | 2
Treatment adherence | 4 | 1 | 2
Weight management | 6 | 6 | 1
Provider-level Outcomes (none)
System-level Outcomes
Access to care | 2
Cost | | | 1 | | 1
Economic outcomes | 1 | | 1
Quality of care indicators | 1 | | 1
Utilization | 1 | | 1 | | 2
No Clear Primary Outcome | 12 | 7 | 4