# APPENDIX C Study Characteristics Table

This table shows characteristics for the 209 primary studies by the 7 focused areas of research. For full study citations, please refer to the report’s main reference list.

Study | Study N | Primary Telehealth Modality | Outcome Level(s) | Setting(s)
Maternal Health (n=81)
Ahmed, 2016^35^ | 141 | Interactive website | Patient | Inpatient
Albright, 2014^36^ | 311 | Phone | Patient | Community
Alemi, 1996^37^ | 178 | Interactive website | Patient | Outpatient
Althuizen, 2013^38^ | 119 | Phone | Patient | Outpatient
Amiri, 2016^39^ | 100 | Phone | Patient | Outpatient
Bagherinia, 2016^40^ | 136 | Phone | Patient | Outpatient
Bartholomew, 2015^111^ | 100 | Phone | Patient | Inpatient
Brooten, 2001^41^ | 173 | Phone | Patient, system | Inpatient
Bryce, 1991^42^ | 1970 | Phone | Patient | Outpatient
Bunik, 2010^43^ | 341 | Phone | Patient | Outpatient
Carlsen, 2013^44^ | 226 | Phone | Patient, system | Inpatient
Chapman, 2004^45^ | 219 | Phone | Patient | Outpatient
Cummins, 2016^46^ | 1173 | Phone | Patient | Community
Cupples, 2011^47^ | 343 | Phone | Patient | Outpatient
Curry, 2006^48^ | 489 | Phone | Patient | Outpatient
Dalfra, 2009^49^ | 276 | Phone | Patient | Outpatient
Dennis, 2002^50^ | 256 | Phone | Patient, provider | Community
Dennis, 2002^51^ | 256 | Phone | Patient | Inpatient
Dennis, 2009^52^ | 701 | Phone | Patient | Community
Dodd, 2014^53^ | 2212 | Phone | Patient | Outpatient
Dornelas, 2006^54^ | 105 | Phone | Patient, system | Outpatient
Eden, 2014^55^ | 131 | Interactive website | Patient | Community
Efrat, 2015^56^ | 289 | Phone | Patient | Community
Ershoff, 1999^33^ | 390 | Phone | Patient | Outpatient
Fenwick, 2015^57^ | 339 | Phone | Patient | Outpatient
Ferrara, 2016^58^ | 2280 | Phone | Patient, system | Outpatient
Frank, 1987^59^ | 343 | Phone | Patient | Outpatient
Fu, 2014^60^ | 722 | Phone | Patient | Inpatient
Gao, 2015^65^ | 180 | Phone | Patient | Inpatient
Gao, 2012^64^ | 194 | Phone | Patient | Outpatient
Gao, 2010^63^ | 194 | Phone | Patient | Outpatient
Gagnon, 1997^61^ | 183 | Phone | Patient | Outpatient
Gamble, 2005^62^ | 103 | Phone | Patient | Outpatient
Giallo, 2014^66^ | 202 | Phone | Patient | Community
Gu, 2016^67^ | 352 | Phone | Patient | Inpatient
Hannan, 2016^68^ | 129 | Phone | Patient, system | Inpatient
Hannover, 2009^69^ | 871 | Phone | Patient | Inpatient
Hillesund, 2016^70^ | 606 | Phone | Patient | Outpatient
Huang, 2013^71^ | 355 | Phone | Patient | Outpatient
Janssen, 2006^73^ | 1459 | Phone | Patient | Outpatient
Janssen, 2013^72^ | 1459 | Phone | Patient | Outpatient
Jiang, 2014^74^ | 582 | SMS/text messaging | Patient | Community
Jiang, 2014^75^ | 771 | Phone | Patient | Community
Jordan, 2015^76^ | 18,186 | SMS/text messaging | Patient | Community
Kamalifard, 2013^77^ | 100 | Phone | Patient | Community
Lewis, 2014^78^ | 130 | Phone | Patient | Community
Lund, 2012^79^ | 2550 | SMS/text messaging | System | Outpatient
Mangwi Ayiasi, 2016^80^ | 1385 | Phone | Patient, system | Community
Maslowsky, 2016^81^ | 178 | Phone | Patient | Inpatient
McBride, 2004^82^ | 583 | Phone | Patient | Other
Milgrom, 2011^83^ | 143 | Phone | Patient | Outpatient
Mohammad-Alizadeh-Charandabi, 2013^84^ | 366 | Phone | Patient | Inpatient
Moore, 1998^85^ | 1544 | Phone | Patient, system | Community
Muender, 2000^86^ | 1544 | Phone | Patient, system | Community
Naughton, 2012^87^ | 207 | SMS/text messaging | Patient | Community
Ngai, 2016^89^ | 397 | Phone | Patient | Inpatient
Ngai, 2015^88^ | 397 | Phone | Patient | Inpatient
Niela-Vilen, 2016^90^ | 124 | Facebook | Patient | Other
Oakley, 1990^91^ | 509 | Phone | Patient | Outpatient
Odeny, 2014^92^ | 388 | SMS/text messaging | System | Outpatient
O’Reilly, 2016^93^ | 573 | Phone | Patient | Community
Ostbye, 2009^94^ | 450 | Phone | Patient | Outpatient
Phelan, 2014^95^ | 401 | Phone | Patient | Outpatient
Phelan, 2011^96^ | 401 | Phone | Patient | Outpatient
Reeder, 2014^21^ | 1885 | Phone | Patient | Community
Sagedal, 2017^99^ | 606 | Phone | Patient | Outpatient
Sagedal, 2016^98^ | 606 | Phone | Patient | Outpatient
Sagedal, 2017^97^ | 606 | Phone | Patient | Community
Seguranyes, 2014^100^ | 1598 | Video conference to home | Patient, system | Outpatient
Serwint, 1991^101^ | 251 | Phone | Patient | Outpatient
Simmons, 2016^17^ | 436 | Phone | Patient | Outpatient
Snaith, 2014^22^ | 840 | Phone | Patient, provider | Community
Srinivas, 2015^102^ | 103 | Phone | Patient | Outpatient
Stotts, 2002^103^ | 269 | Phone | Patient, system | Community
Surkan, 2012^104^ | 679 | Phone | Patient | Community
Tahir, 2013^105^ | 357 | Phone | Patient | Inpatient
Takeuchi, 2016^106^ | 161 | Mobile application | Patient | Inpatient
Toohill, 2014^107^ | 339 | Phone | Patient | Outpatient
Wang, 2014^108^ | 106 | Phone | Patient | Outpatient
Wilton, 2013^109^ | 132 | Phone | Patient, system | Community
Wong, 2007^110^ | 200 | Phone | Patient, provider | Inpatient
Prevention (n=56)
Annesi, 2016^113^ | 107 | Phone | Patient | Community
Befort, 2016^114^ | 172 | Phone | Patient, system | Community
Bloom, 2006^115^ | 157 | Phone | Patient | Outpatient
Bullock, 2009^116^ | 695 | Phone | Patient | Community
Cadmus-Bertram, 2016^117^ | 105 | Phone | Patient | Outpatient
Chen, 1998^118^ | 125 | Phone | Patient | Community
Conn, 2003^30^ | 190 | Phone | Patient | Community
Conway, 2004^119^ | 2781 | Phone | Patient | Other
Corkrey, 2005^120^ | 17,008 | Phone | Patient | Community
Curry, 2003^121^ | 303 | Phone | Patient | Outpatient
Demark-Wahnefried, 2015^122^ | 692 | Phone | Patient | Outpatient
Dietrich, 2006^29^ | 1413 | Phone | Patient | Outpatient
Dietrich, 2007^123^ | 1316 | Phone | Patient | Outpatient
Dietrich, 2013^124^ | 2240 | Phone | Patient | Outpatient
Eaker, 2004^125^ | 12,240 | Phone | Patient | Community
Eakin, 2012^126^ | 143 | Phone | Patient | Inpatient
Fjeldsoe, 2015^127^ | 263 | SMS/text messaging | Patient | Community
Goodwin, 2014^128^ | 338 | Phone | Patient | Outpatient
Gordon, 2016^129^ | 194 | Phone | Patient, system | Outpatient
Han, 2017^130^ | 560 | Phone | Patient | Community
Harrigan, 2016^131^ | 100 | Phone | Patient | Outpatient
Hayes, 2011^132^ | 194 | Phone | Patient | Community
Hayes, 2013^133^ | 194 | Phone | Patient | Outpatient
Helmes, 2006^134^ | 340 | Phone | Patient | Outpatient
Hou, 2005^135^ | 424 | Phone | Patient | Inpatient
Kerr, 2008^136^ | 401 | Phone | Patient | Outpatient
Keyserling, 2002^138^ | 200 | Phone | Patient, provider | Community
Keyserling, 2008^137^ | 236 | Phone | Patient | Outpatient, community
Koniak-Griffin, 2015^139^ | 223 | Phone | Patient | Community
Lawton, 2008^140^ | 1089 | Phone | Patient | Outpatient
Lawton, 2009^141^ | 1089 | Phone | Patient, system | Community
Lee, 2001^142^ | 102 | Phone | Patient | Community
Lopez-Torres Hidalgo, 2016^143^ | 263 | SMS/text messaging | Patient, provider | Community
Manfredi, 2004^144^ | 1068 | Phone | Patient | Outpatient
Maskarinec, 2003^145^ | 220 | Phone | Patient | Outpatient
McBride, 1999^146^ | 580 | Phone | Patient | Outpatient
McClure, 2005^147^ | 275 | Phone | Patient | Other
Miller, 1997^148^ | 395 | Phone | Patient | Outpatient
Nies, 2003^149^ | 197 | Phone | Patient | Community
Parra-Medina, 2011^150^ | 266 | Phone | Patient | Outpatient
Paskett, 2011^151^ | 286 | Phone | Patient | Outpatient
Peshkin, 2016^152^ | 554 | Phone | Patient | Outpatient
Pierce, 2004^154^ | 2970 | Phone | Patient | Outpatient
Pierce, 2006^153^ | 2922 | Phone | Patient | Community
Pinto, 2013^155^ | 192 | Phone | Patient | Outpatient
Rimer, 1999^157^ | 889 | Phone | Patient | Community
Rigotti, 2006^156^ | 442 | Phone | Patient | Outpatient
Rock, 2010^159^ | 446 | Phone | Patient | Inpatient
Rock, 2015^158^ | 692 | Phone | Patient | NR
Sivarajan Froelicher, 2004^160^ | 277 | Phone | Patient | Inpatient
Solomon, 2005^161^ | 330 | Phone | Patient | Community
Stein, 2005^162^ | 1140 | Phone | Patient, system | Community
Steinberg, 2014^163^ | 194 | IVR, brief tailored feedback | Patient | Outpatient
Valanis, 2002^32^ | 510 | Phone | Patient | Community
Wetter, 2011^164^ | 302 | Mobile application | Patient | Community
Wilbur, 2016^18^ | 288 | Phone | Patient | Community
Disease Management (n=43)
Allard, 2007^165^ | 117 | Phone | Patient | Outpatient
Aranda, 2006^166^ | 105 | Phone | Patient | Outpatient
Ashing, 2014^167^ | 221 | Phone | Patient | Community
Baker, 2011^23^ | 450 | Interactive website | Patient, provider | Outpatient
Bastani, 2010^168^ | 1708 | Phone | System | Outpatient
Budin, 2008^169^ | 249 | Phone | Patient | Other
Caljouw, 2010^170^ | 499 | Phone | Patient | Outpatient
Crane-Okada, 2012^171^ | 139 | Phone | Patient | Outpatient
Damholdt, 2016^172^ | 157 | Interactive website | Patient | Community
Davison, 2002^173^ | 749 | Interactive website | Patient | Outpatient
Ell, 2009^174^ | 487 | Phone | Patient | Outpatient
Freeman, 2015^20^ | 118 | Phone, video conference to home | Patient | Community
Gallagher, 2003^175^ | 196 | Phone | Patient | Inpatient
Gustafson, 2005^176^ | 231 | Phone | Patient, system | Outpatient, inpatient
Hageman, 2014^177^ | 289 | Interactive website | Patient | Community
Hawkins, 2010^26^ | 434 | Phone control, e-health web-based CHESS, interactive website | Patient | Outpatient
Hawkins, 2011^34^ | 434 | Phone, interactive website | Patient | Outpatient
Hoyer, 2011^178^ | 100 | Phone | Patient | Outpatient
Kimman, 2011^24^ | 320 | Phone | System | Outpatient
Kimman, 2011^25^ | 299 | Phone | Patient | Outpatient
Kleiboer, 2014^179^ | 368 | Interactive website | Patient | Outpatient
Kristjansdottir, 2013^180^ | 140 | Mobile application | Patient | Inpatient
Lin, 2016^181^ | 115 | Phone | Patient | Community
Marcus, 2010^182^ | 304 | Phone | Patient | Outpatient, inpatient
Miller, 2013^183^ | 210 | Phone | Patient | Outpatient
Mishel, 2005^184^ | 509 | Phone | Patient | Outpatient, inpatient, community
Parsapure, 2016^197^ | 350 | Phone | Patient | Outpatient
Pierce, 2007^186^ | 3082 | Phone | Patient | Other
Pierce, 2007^185^ | 3107 | Phone | Patient | Outpatient
Rock, 2001^196^ | 1010 | Phone | Patient | Community
Salonen, 2009^188^ | 250 | Phone | Patient | Outpatient
Salonen, 2011^187^ | 164 | Phone | Patient | Inpatient
Samarel, 2002^31^ | 125 | Phone | Patient | Outpatient, inpatient
Sandgren, 2007^28^ | 218 | Phone | Patient | Outpatient
Sherman, 2012^27^ | 249 | Phone | Patient | Outpatient
Sjostrom, 2015^190^ | 250 | Email/secure message | Patient | Community
Sjostrom, 2015^189^ | 250 | Interactive website | Patient, system | Community
Sjöström, 2015^191^ | 250 | Interactive website | Patient | Other
Skelly, 2009^192^ | 180 | Phone | Patient | Outpatient, community
Stuifbergen, 2010^193^ | 187 | Phone | Patient | Community
Tso, 2015^19^ | 6591 | Phone | Patient | Other
Wenzel, 2015^194^ | 204 | Phone | Patient | Other
Ziller, 2013^195^ | 181 | Phone | Patient | Outpatient
Family Planning (n=11)
Ayiasi, 2015^198^ | 1385 | Phone | Patient | Outpatient
Berenson, 2012^199^ | 1155 | Phone | Patient | Outpatient
Gerris, 2014^200^ | 123 | Patient-generated images | Patient, system | Outpatient
Hameed, 2016^201^ | 1246 | Phone | Patient | Outpatient
Ngoc, 2014^202^ | 1433 | Phone | Patient | Outpatient
Paul, 2015^203^ | 731 | Phone | Patient | Outpatient
Schover, 2011^204^ | 300 | Phone | Patient | Community
Skiadas, 2011^208^ | 131 | Phone | Patient | Outpatient
Smith, 2015^205^ | 500 | Phone | Patient | Outpatient
Sridhar, 2015^206^ | 120 | Interactive website | Patient | Outpatient
Tsur, 2008^207^ | 108 | Phone | Patient | Community
High-risk Breast Cancer Assessment (n=7)
Bloom, 2006^209^ | 163 | Phone | Patient | Community
Chang, 2016^210^ | 901 | Phone | System | Outpatient
Jenkins, 2007^211^ | 111 | Phone | Patient | Other
Kinney, 2014^212^ | 1012 | Phone | Patient, system | Other
Kinney, 2016^213^ | 988 | Phone | Patient, system | Community
Schwartz, 2014^214^ | 669 | Phone | Patient, system | Outpatient
White, 2014^215^ | 207 | Phone | Patient | Outpatient
Mental Health (n=6)
Beaver, 2009^216^ | 374 | Phone | Patient, provider | Outpatient
de Bie, 2011^217^ | 169 | Phone | Patient | Outpatient
Gotay, 2007^218^ | 305 | Phone | Patient | Outpatient
Ireys, 2001^219^ | 139^a^ | Phone | Patient | Outpatient
Morland, 2015^221^ | 126 | Video conference to other clinic(s) | Patient | Community
Tiwari, 2010^220^ | 200 | Phone | Patient | Community
Intimate Partner Violence (n=5)
Abrahams, 2010^226^ | 279 | Phone | Patient | Community
McFarlane, 2004^222^ | 150 | Phone | Patient | Community
Stevens, 2015^224^ | 253 | Phone | Patient | Outpatient
Saftlas, 2014^223^ | 307 | Phone | Patient | Outpatient
Tiwari, 2012^225^ | 200 | Phone | Patient | Community

a 139 mothers analyzed of 161 enrolled.

Abbreviations: CHESS=Comprehensive Health Enhancement Support System; IVR=interactive voice response; SMS=short message system