# APPENDIX B Peer Review Comments

Question Text | Reviewer Number | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | 1 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described? | 3 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described? | 4 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described? | 5 | No - The inclusions/exclusions criteria for study design are quite rigorous so that few non-RCTs were included. The objectives and scope should be modified to more accurately reflect this very focused review. The study selection and data abstraction sections are likely to be confusing to some readers. | Thank you for this point and the need for clarification. For this evidence map, we used EPOC criteria^*^ to identify study designs that provide higher quality information to inform the guiding question. Of note, EPOC does allow non-RCTs, though admittedly we did not identify many.
Are the objectives, scope, and methods for this review clearly described? | 6 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described? | 8 | Yes | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 1 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 3 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 4 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 5 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 6 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 8 | No | Acknowledged
Are there any [underlined: published] or u[underlined: npublished] studies that we may have overlooked? | 1 | Yes - The report clearly states that the objective is “to describe the current landscape of telehealth interventions that have been designed specifically for women”. However, does it make sense to acknowledge (and perhaps also list/review) the telehealth trials/research that included both men and women veterans? While some health areas in the report are clearly female sex specific, whereas mental health, for example, is not. Some of the extant studies report sex differences in outcomes, which are germane for informing programs and improvements in treatment delivery for both women and men. A rationale for why NOT to include studies with both sexes may be helpful or at least acknowledgement of this limitation. | This reviewer brings up a key distinction that we gave a significant amount of thought to in the design of this map. There were a couple of reasons that we did not include gender-neutral studies that may have included sex-based analyses. First, this project was developed in response to a question from our operational partners that specifically asked about telehealth interventions “designed specifically for women.” If an intervention included both men and women—but was not designed specifically for women or for a female-predominant condition—then we considered it not to be designed for women in particular. Second, in a previous ESP project, we conducted an evidence map assessing sex and gender-based analysis in trials of depression, diabetes and chronic pain.^*^ In that evidence map, we found that only 10% of eligible reviews including analyses of sex effects. We agree that adding this rationale to the report is important and have done so in the methods section under “topic development” and in the limitations.
Are there any [underlined: published] or u[underlined: npublished] studies that we may have overlooked? | 3 | No | Acknowledged
Are there any [underlined: published] or u[underlined: npublished] studies that we may have overlooked? | 4 | No | Acknowledged
Are there any [underlined: published] or u[underlined: npublished] studies that we may have overlooked? | 5 | Yes - The criteria were strict in terms of study design so that few non-RCTs were included. Care should be taken in stating the objectives and summary to state the effect of these strict criteria on the body of literature included. For example, RCTs are much easier to conduct with randomized patient groups rather than provider or system groups, thus it is not surprising that the findings overwhelmingly include patient groups and not provider or system groups. Likewise RCTs are easier to implement with short-duration interventions and telephone interventions. Thus, the interpretation of the existing literature is likely biased by adhering to this strict criteria. And the studies selected clearly do not reflect the entire literature. I suggest that the authors be a little clearer in stating the conclusions but also the objective of the evidence map - it is a selected evidence map reflecting the most rigorous study designs. This does not lessen its importance, but its strict focus must be made clear and the conclusions should be interpreted in this light. | As noted above, we focused on the inclusion of studies meeting EPOC criteria, which allows for inclusion of non-RCT designs (nonrandomized controlled trials, controlled before-after CBA, interrupted time series, and repeated measures studies). We allowed provider- and system-focused trial designs, but did not find many meeting the EPOC standards. We agree there may be more provider- and system-focused trials that were observational or other designs without a comparator group that we did not include and that much could be learned from this literature. However, as our operational partners were interested in understanding the scope of existing literature that could contribute to our understanding of the effectiveness of telehealth interventions, we limited those studies we included to those that could potentially provide this information. We have added this caveat in the limitations as suggested.
Are there any [underlined: published] or u[underlined: npublished] studies that we may have overlooked? | 6 | No | Acknowledged
Are there any [underlined: published] or u[underlined: npublished] studies that we may have overlooked? | 8 | No | Acknowledged
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | Please define “virtual visits”. This term has several possible meaning these days, including web-based services, virtual reality, and others. This is an excellent report. Thank you. | We agree that terms such as “virtual visit” can have many different interpretations. We have replaced this term in the introduction for specific examples of the types of telehealth that the VA supports. Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 4 | This was an excellent report. I just had a few minor comments:; 1) I am not sure how much the length of the intervention matters, it seems like this would depend on the condition/population being targeted so in aggregate isn’t too informative. Is there a way to look instead at intensity of the intervention (number of contacts, number of potential contacts, or similar)?; 2) In the intro you provide a sentence for an overview of telehealth, but it might be helpful to have a more formal definition and references (inclusion and exclusion criteria do provide this indirectly, but having 1-2 sentences would be helpful.; 3) on page 44 there is mention made of the challenges for pregnant veterans related to mental health. I think that the references you want are:; - Shaw, J. G., et al. (2014). “Posttraumatic stress disorder and risk of spontaneous preterm birth.” Obstet Gynecol 124(6): 1111-1119.; - Shaw, J. G., et al. (2017). “Post-traumatic Stress Disorder and Antepartum Complications: a Novel Risk Factor for Gestational Diabetes and Preeclampsia.” Paediatr Perinat Epidemiol 31(3): 185-194.; and possibly:; - Katon, J. G., et al. (2017). “Improving Perinatal Mental Health Care for Women Veterans: Description of a Quality Improvement Program.” Matern Child Health J 21(8): 1598-1605.; - Mattocks, K. M., et al. (2017). “Implementing and Evaluating a Telephone-Based Centralized Maternity Care Coordination Program for Pregnant Veterans in the Department of Veterans Affairs.” Womens Health Issues.; Otherwise there were a few minor typos, but it was an excellent report. | 1) We agree that understanding the dose or intensity of a telehealth intervention might be more informative that the length of the intervention. However, we did not collect this information for a couple of reasons. First, based on prior work on a health coaching systematic review,^*^ we found collecting this kind of information to be tremendously challenging. Interventions often do not report this information consistently or at all and because different interventions may use entirely different modalities (eg, fax vs telephone vs SMS/text messaging) it is not clear how to compare this across modality. Further, we know that publications about interventions rarely describe the dose of an intervention.^**^ In the case of this evidence map, we found that intervention intensity as planned per protocol and adherence to the planned intervention was not commonly reported.; 2) Thank you. We have further delineated what telehealth is in the Introduction. We have added the following from HRSA “According to Health Resources and Service Administration (HRSA),^*^ telehealth is defined as “the use of electronic information and telecommunication technologies to support and promote long-distance clinical health care, patient and professional health-related education, public health and health administration.”; 3) Thank you for these references, we have added them as suggested in the report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 5 | 1) Overall, this is a very well conducted evidence map and report. My comments are largely suggestions to clarify some of the text for the reader.; 2) Abstract, page 1, line 26 – It would help the reader if a little bit of information is given on what the predetermined criteria are, since these criteria have a major impact on the evidence map.; 3) Abstract, page 2, line 33 and elsewhere – IPV should be spelled out since it is not an obvious abbreviation to all readers.; 4) Study Selection, page 4 – This paragraph is a little confusing. For example, the sentence beginning on line 38 is not clear whether the inter-rater reliability was computed at the title/abstract stage or at an early stage of full-text screening. And it is not clear whether the dual-review process specifically involved the single trained reviewer plus the second review on 20% or something else. Also, it becomes obvious later on that all inclusion criteria needed to be met but this should be explicitly stated and whether missing information on criteria was or was not a reason for exclusion.; 5) Table 1 is very clear.; 6) Data Abstraction, page 6 line 36 – Reaching consensus on only 10% of cases does not help with any discrepancies that might have arisen on the remaining 90% had they been reviewed. I completely understand the work involved in this type of undertaking, but the study selection and data abstraction processes largely involved a single person, which could have led to missed literature and/or misstated data and this should be clearly stated as a limitation.; 7) Results, page 8 and 9 – Figure 1 is clear. The presentation of findings is clearly organized and will be particularly helpful to the reader. Table 2 is a useful summary of the classification of studies.; 8) Key Question, page 9 line 4 – Since the inclusion criteria were quite rigorous in terms of study sample size and research design, which led to very few non RCTs being included, the findings are really limited to large RCTs. Thus, the Key Question should be modified to reflect that the evidence summarized was the most rigorous of studies.; 9) Figure 2, page 11 – It will help the reader if all figures of this type are enlarged. I suggest moving Panel IV to follow Panel I. Panel IV includes two items that are more reflective of the sample characteristics and thus will nicely follow Panel I. I suggest that Panel V be labeled “Outcome Level” to be clearer to the reader. Note that Figures 5 and 6 are in the opposite order of Panels III and IV.; 10) Systematic Review Findings, page 12 – Specific references and findings are provided here but nowhere else, and since this comes early in the report it will likely confuse the reader. I suggest deleting this level of detail. I also suggest moving the systematic review findings section for maternal health to come at the end of this section as you have done in the Intimate Partner Violence section.; 11) Limitations, page 39, line 8 – This last sentence is very important and should appear in the objectives and be reflected in the Key Question.; 12) Research Gaps/Future Research, page 39, line 37 – Here is an example of the implication of only including “studies of higher methodological rigor such as RCTs”. RCTs are difficult to conduct and randomizing patients is much easier than randomizing providers or systems.; 13) Also, only including studies with over 100 participants, means that the participants are likely to be patients rather than providers or systems. Also, the fact that the interventions tended to be by phone and of brief duration is likely a result of the studies being RCTs. This results in a chicken-andegg situation where the inclusion/exclusion criteria were so strict that they drove the type of literature that was included. A reader might interpret the Research Gaps/Future Research section as suggesting that only a small literature on other outcomes and on non-telephone interventions exists, which could be a faulty conclusion. I am not suggesting that this report lacks merit – it is well done and a definite contribution – I am only suggesting that a few statements in the Key Question and Discussion section be qualified more clearly.; 14) Appendix C was clearly a lot of work – I did not see it discussed anywhere. | 1) Thank you; 2) We appreciate this suggestion and have added content at this location to clarify the criteria used.; 3) This suggestion is appreciated and we have made the recommended changes.; 4) We understand this section being confusing and have clarified it as suggested. If we could not confirm that a particular study met our inclusion criteria due to missing information, we excluded it. We have added this to the methods description.; 5) Thank you.; 6) We have added this as a limitation.; 7) Thank you. We are glad the reviewer found this helpful.; 8) We have added this to the limitations. Further, we have clarified that our original intent was to map the literature assessing the effectiveness of telehealth strategies for women in our key question, abstract, and Methods. Thus, inclusion of EPOC studies is most relevant.; 9) We appreciate these suggestions to improve the usefulness and clarity of our figures and have made the adjustments as noted.; 10) We appreciate that the reviewer identified this difference in detail for the systematic review sections. We elected to keep this additional detail in these areas as we hoped it would provide a small amount of information about efficacy which was limited by the nature of this evidence map.; 11) As noted above, we agree that this caveat needs to be acknowledged and have added it to the limitations section. Further, we have clarified our original intent and added language about mapping the literature assessing the effectiveness of interventions approaches to the abstract, Methods and key question.; 12) As noted, we have added detail in the objectives about the rationale for included studies of higher methodologic rigor, including nonrandomized designs as recommended by EPOC to assess system-level interventions.; 13) We acknowledge that this is a valid concern. For clarification, we note that the inclusion criteria was operationalized to mean that studies had to include at least 100 patients participants even if the unit of randomization or study was providers or systems. However, you are right that the unit of analysis was the patient. We have added clarification about the rationale for our approach and strengthened the discussion of this limitation.; 14) Thank you. The results of this table are discussed in the context of the finding of the focused areas of research. We also direct readers to this table at the beginning of the results section so they can see the individual studies, and some key characteristics, associated with each focused area of research.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 6 | 1) Regarding potential for overlooked studies, it seems they did a comprehensive search, but I am not sure when I say no to item above on “any published or unpublished studies.; 2) A more definitive set of suggestions for specific VA sponsored research would be a useful addition perhaps considering the potential power of the VA for multi-institutional trials leveraging the quite ubiquitous telemedicine applications and what levels of participation or design to address the identified gaps might be considered.; 3) Also useful would be the age of the publications - what is the spectrum of currency of the literature reviewed? | 1) Thank you. We sought to do a thorough mapping of this literature.; 2) We appreciate this suggestion and agree that this would be a useful addition to the report. Thus, we have added content to suggest that given the nature of the large and diverse VA care system and the extent to which the VA has invested in telehealth modalities, there are many opportunities to pursue multi-site trials. We cite prior studies that have utilized multi-site approaches to study approaches to care provision as examples that could be considered in developing women’s telehealth specific studies.^*^ Specifically we point to infrastructures such as the WH-PBRN as a possible resource for pursuing a multisite trial of telehealth services for women.; 3) As noted in the methods section, our search strategy was limited by the inception date of the databases used. Of those studies found meeting inclusion criteria, the earliest study was published in 1987 and the search is current through December 2016. The publication dates of included studies are listed in Table 2.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 8 | 1) The topic is very timely and important to the VA, for reasons discussed in the review.; 2) The review would have benefited from a clear definition (and differentiation) of the various virtual care technologies (e.g., telemedicine, telehealth, eHealth, mHealth) and to use this definition to describe the studies.; 3) In addition, it would have been helpful to see specific search terms.; 4) Looking forward, a limitation of the literature (and thus the review) is that 86% of the studies focused on telephone as the telemedicine technology. Thus, relatively little can be concluded about more innovative forms of telemedicine, beyond the telephone; 5) Only thrice (page 22 – disease management; page 28 – mental health; page 31 IPV) did the review mention what % of studies were VA studies. Moreover, the location of this information was not consistent. I suggest adding a bullet to each key point stating % of studies conducted with Veterans or VA enrollees.; 6) The biggest weakness of the review is that while the outcomes measured were reported, no actual intervention effects were reviewed. Where the primary outcomes improved? What was the effect size? Did the secondary outcomes improve and what was the effect size? This is listed as a limitation by the authors, but the justification for not reporting outcomes seemed weak/non-existent. Given that the studies were categorized into fairly homogenous groups, outcomes could have been examined.; 7) Figures 13–16 seemed redundant with the figures presented earlier. | 1) Thank you.; 2) We agree that the term telehealth can be used a number of different ways and clarifying this aspect of our project is key. We have added a clear definition to the topic development section that pulls together the inclusion criteria we used and identifies the terminology that we use throughout the rest of the report.; 3) Exact search terms are in Appendix A.; 4) We agree that this is a significant gap in the literature and have added emphasis to this point in the section on “research gaps/future research.”; 5) We agree that this is an important point, and have added a bullet in the key points about the number of studies for each section that was conducted in the Veteran population.; 6) We appreciate and understand the interest in an exploration and meta-analysis of actual intervention effects. However, given the nature of this project as an evidence map rather than a systematic review, this level of analysis was beyond the scope of what was requested by our operations partners. The purpose of an evidence map^*^ is not to provide the summary estimates of effects but to conduct “a systematic search of a broad field to identify gaps in knowledge and/or future research needs that presents results in a user-friendly format, often a visual figure or graph, or a searchable database.” We have added clarification about this intent in the “topic development” section to clarify this approach for readers.; 7) Figures 13–16 do provide previously presented information, however organized into a different way to facilitate additional comparisons. In the body of the results, we present study characteristics by focused research area (eg, maternal health, prevention). For the summary, we chose to reorganize this information to allow for synthesis across all the areas of research within women’s telehealth by key study characteristics to offer a user-friendly way to compare across focused areas of research.

* Effective Practice and Organisation of Care (EPOC). EPOC Resources for review authors. Oslo: Norwegian Knowledge Centre for the Health Services; 2015. Available at: http://epoc.cochrane.org/epoc-specific-resources-review-authors2015.

* Duan-Porter W, et al. Reporting of Sex Effects by Systematic Reviews on Interventions for Depression, Diabetes, and Chronic Pain. Ann Intern Med. 2016 Aug 2;165(3):184-93. doi: 10.7326/M15-2877. Epub 2016 Apr 26. PubMed PMID: 27111355.

* Gierisch JM, et al. The Effectiveness of Health Coaching. VA ESP Project #09-009; 2016

** King H., BOSWORTH (2015). Treatment Fidelity in Health Services Research. In Sanetti L (ed.) Treatment Integrity: Conceptual, Methodological, and Applied Considerations for Practitioners. Washington DC, American Psychological Association. Pp. 15-34.

* https://www.hrsa.gov/rural-health/telehealth/index.html

* Goldstein KM, et al. Practice-based research networks add value to evidence-based quality improvement. Healthc (Amst). 2017.

* Miake-Lye IM, et al. What is an evidence map? A systematic review of published evidence maps and their definitions, methods, and products. Syst Rev. 2016;5:28.