# APPENDIX A Search Strategies

## PubMed search date: December 29, 2016

Set | Terms | Results
#1 | (“Cell Phones”[Mesh] OR “Text Messaging”[Mesh] OR “Computers, Handheld”[Mesh] OR “Telemedicine”[Mesh] OR “Mobile Applications”[Mesh] OR “mobile applications”[tiab] OR “mobile application”[tiab] OR cellphone[tiab] OR cellphones[tiab] OR ((mobile[tiab] OR cellular[tiab] OR cell[tiab]) AND (phone[tiab] OR phones[tiab] OR device[tiab] OR devices[tiab] OR app[tiab] OR apps[tiab])) OR mobiles[tiab] OR smartphone[tiab] OR smartphones[tiab] OR telephone[tiab] OR telephones[tiab] OR phone[tiab] OR phones[tiab] OR e-health[tiab] OR ehealth[tiab] OR m-health [tiab] OR mhealth[tiab] OR telehealth[tiab] OR telemedicine[tiab] OR video-conference[tiab] OR videoconference[tiab] OR video-conferencing[tiab] OR videoconferencing[tiab] OR “automated telephone”[tiab] OR IVR[tiab] OR “interactive voice response”[tiab] OR sms[tiab] OR skype[tiab] OR (text[tiab] AND (message[tiab] OR messages[tiab])) OR texts[tiab] OR mms[tiab] OR blackberry[tiab] OR ipad[tiab] OR ipads[tiab] OR android[tiab] OR laptop[tiab] OR laptops[tiab] OR ((tablet[tiab] OR tablets[tiab]) AND (computer[tiab] OR computers[tiab] OR device[tiab] OR devices[tiab]))) | 144064
#2 | women[mesh] OR “Reproductive Health Services”[Mesh] OR “Women’s Health”[Mesh] OR “Women’s Health Services”[Mesh] OR “Gynecologic Surgical Procedures”[Mesh] OR “Pregnancy”[Mesh] OR “Pregnancy Complications”[Mesh] OR “Pregnant Women”[Mesh] OR “Mammography”[Mesh] OR “Gynecological Examination”[Mesh] OR “Female Urogenital Diseases”[Mesh] OR “Breast Diseases”[Mesh] OR “Breast Feeding”[Mesh] OR “Lactation”[Mesh] OR “Contraception”[Mesh] OR “Contraceptives, Oral”[Mesh] OR “Depression, Postpartum”[Mesh] OR “Uterine Cervical Neoplasms”[Mesh] OR “Papanicolaou Test”[Mesh] OR “Breast Neoplasms”[Mesh] OR “Sex Offenses”[Mesh] OR “Domestic Violence”[Mesh] OR “Intimate Partner Violence”[Mesh] OR “Migraine Disorders”[Mesh] OR “Genetic Counseling”[Mesh] OR “Fibromyalgia”[Mesh] OR women[ti] OR colposcopy[tiab] OR pregnancy[tiab] OR pregnant[tiab] OR breastfeeding[tiab] OR “breast feeding”[tiab] OR lactation[tiab] OR “breast health”[tiab] OR prenatal[tiab] OR “reproductive health”[tiab] OR “family planning”[tiab] OR contraception[tiab] OR contraceptive[tiab] OR contraceptives[tiab] OR “postpartum depression”[tiab] OR “gestational diabetes”[tiab] OR preeclampsia[tiab] OR “pre-eclampsia”[tiab] OR preconception[tiab] OR “pre-conception”[tiab] OR perinatal[tiab] OR maternal[tiab] OR “cervical cancer”[tiab] OR “Papanicolaou Test”[tiab] OR “pap test”[tiab] OR “Breast cancer”[tiab] OR “intimate partner violence”[tiab] OR rape[tiab] OR (sexual[tiab] AND (violence[tiab] OR trauma[tiab])) OR migraine[tiab] OR migraines[tiab] OR “genetic counseling”[tiab] OR fibromyalgia[tiab] | 2641700
#3 | #1 AND #2 | 13936
#4 | telecolposcopy[tiab] OR “tele-colposcopy”[tiab] OR telegynecology[tiab] OR “tele-gynecology”[tiab] OR “telemental health”[tiab] OR “tele mental health”[tiab] OR telepharmacy[tiab] OR “tele-pharmacy”[tiab] OR “teleprimary care”[tiab] OR “tele primary care”[tiab] OR “telewellness”[tiab] OR “tele wellness”[tiab] OR “telecare coordination”[tiab] OR “tele care coordination”[tiab] | 200
#5 | #3 OR #4 | 14119
#6 | (systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR “Comparative Study”[Publication Type] OR “Controlled Clinical Trial”[Publication Type] OR Non-random[tiab] OR nonrandom[tiab] OR nonrandomized[tiab] OR non-randomized[tiab] OR nonrandomized[tiab] OR non-randomised[tiab] OR quasi-experiment*[tiab] OR quasiexperiment*[tiab] OR quasirandom*[tiab] OR quasi-random*[tiab] OR quasi-control*[tiab] OR quasicontrol*[tiab] OR (controlled[tiab] AND (trial[tiab] OR study[tiab]))) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) | 3258507
#7 | #5 AND #6 | 5038
#8 | #7 NOT ((“Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh]) NOT “Adult”[Mesh]) AND English[la] | 4486

## Embase search date: December 29, 2016

Set | Terms | Results
#1 | ‘mobile phone’/exp OR ‘text messaging’/exp OR ‘personal digital assistant’/exp OR ‘telemedicine’/exp OR ‘mobile application’/exp OR ‘mobile applications’:ab,ti OR ‘mobile application’:ab,ti OR cellphone:ab,ti OR cellphones:ab,ti OR ((mobile:ab,ti OR cellular:ab,ti OR cell:ab,ti) AND (phone:ab,ti OR phones:ab,ti OR device:ab,ti OR devices:ab,ti OR app:ab,ti OR apps:ab,ti)) OR mobiles:ab,ti OR smartphone:ab,ti OR smartphones:ab,ti OR telephone:ab,ti OR telephones:ab,ti OR phone:ab,ti OR phones:ab,ti OR ‘e health’:ab,ti OR ehealth:ab,ti OR ‘m-health’:ab,ti OR mhealth:ab,ti OR telehealth:ab,ti OR telemedicine:ab,ti OR ‘video conference’:ab,ti OR videoconference:ab,ti OR ‘video conferencing’:ab,ti OR videoconferencing:ab,ti OR ‘automated telephone’:ab,ti OR IVR:ab,ti OR ‘interactive voice response’:ab,ti OR sms:ab,ti OR skype:ab,ti OR (text:ab,ti AND (message:ab,ti OR messages:ab,ti)) OR texts:ab,ti OR mms:ab,ti OR blackberry:ab,ti OR ipad:ab,ti OR ipads:ab,ti OR android:ab,ti OR laptop:ab,ti OR laptops:ab,ti OR ((tablet:ab,ti OR tablets:ab,ti) AND (computer:ab,ti OR computers:ab,ti OR device:ab,ti OR devices:ab,ti)) | 186383
#2 | ‘female’/mj OR ‘maternal health service’/exp OR ‘birth control’/exp OR ‘women’s health’/exp OR ‘prepregnancy care’/exp OR ‘prenatal care’/exp OR ‘pregnancy’/exp OR ‘gynecologic surgery’/exp OR ‘pregnancy disorder’/exp OR ‘gynecological examination’/exp OR ‘mammography’/exp OR ‘urogenital tract disease’/exp OR ‘breast disease’/exp OR ‘breast feeding’/exp OR ‘breast feeding education’/exp OR ‘lactation’/exp OR ‘lactation disorder’/exp OR ‘oral contraceptive agent’/exp OR ‘puerperal depression’/exp OR ‘uterine cervix cancer’/exp OR ‘Papanicolaou test’/exp OR ‘breast cancer’/exp OR ‘sexual crime’/exp OR ‘domestic violence’/exp OR ‘migraine’/exp OR ‘genetic counseling’/exp OR ‘fibromyalgia’/exp OR women:ti OR colposcopy:ab,ti OR pregnancy:ab,ti OR pregnant:ab,ti OR breastfeeding:ab,ti OR ‘breast feeding’:ab,ti OR lactation:ab,ti OR ‘breast health’:ab,ti OR prenatal:ab,ti OR ‘reproductive health’:ab,ti OR ‘family planning’:ab,ti OR contraception:ab,ti OR contraceptive:ab,ti OR contraceptives:ab,ti OR ‘postpartum depression’:ab,ti OR ‘gestational diabetes’:ab,ti OR preeclampsia:ab,ti OR ‘pre eclampsia’:ab,ti OR preconception:ab,ti OR ‘pre conception’:ab,ti OR perinatal:ab,ti OR maternal:ab,ti OR ‘cervical cancer’:ab,ti OR ‘Papanicolaou Test’:ab,ti OR ‘pap test’:ab,ti OR ‘Breast cancer’:ab,ti OR ‘intimate partner violence’:ab,ti OR rape:ab,ti OR (sexual:ab,ti AND (violence:ab,ti OR trauma:ab,ti)) OR migraine:ab,ti OR migraines:ab,ti OR ‘genetic counseling’:ab,ti OR fibromyalgia:ab,ti | 4111241
#3 | #1 AND #2 | 23689
#4 | telecolposcopy:ab,ti OR ‘tele colposcopy’:ab,ti OR telegynecology:ab,ti OR ‘tele gynecology’:ab,ti OR ‘telemental health’:ab,ti OR ‘tele mental health’:ab,ti OR telepharmacy:ab,ti OR ‘tele pharmacy’:ab,ti OR ‘teleprimary care’:ab,ti OR ‘tele primary care’:ab,ti OR ‘telewellness’:ab,ti OR ‘tele wellness’:ab,ti OR ‘telecare coordination’:ab,ti OR ‘tele care coordination’:ab,ti | 250
#5 | #3 OR #4 | 24079
#6 | ‘evidence based medicine’/exp OR ‘systematic review’:ab,ti OR ‘meta-analysis’:ab,ti OR ‘meta-analyses’:ab,ti OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR ‘clinical trial’:ti,ab OR ‘clinical trials’:ti,ab OR ‘controlled study’/exp OR ‘comparative study’/exp OR Nonrandom:ab,ti OR non-random:ab,ti OR nonrandomized:ab,ti OR nonrandomized:ab,ti OR nonrandomized:ab,ti OR non-randomised:ab,ti OR quasiexperiment*:ab,ti OR quasiexperiment*:ab,ti OR quasirandom*:ab,ti OR quasirandom*:ab,ti OR quasi-control*:ab,ti OR quasicontrol*:ab,ti OR (controlled:ab,ti AND (trial:ab,ti OR study:ab,ti)) AND [humans]/lim AND [english]/lim NOT (’case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp OR [conference abstract]/lim) | 5462927
#7 | #5 AND #6 | 10238
#8 | #7 AND ([young adult]/lim OR [adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) | 7190
#9 | #8 AND [embase]/lim NOT [medline]/lim | 1110