# REFERENCES

1 Hazards O. o. P. H. a. E. Women Veterans Health Care: Facts and Statistics. 2010. cited 2011; Available from: http://www.publichealth.va.gov/womenshealth/facts.asp.
2 Yano EM, et al. Toward a VA Women's Health Research Agenda: setting evidence-based priorities to improve the health and health care of women veterans. J Gen Intern Med. 3. 2006;21:S93-101. [pmid: 16637953].
3 Goldzweig CL, et al. The State of Women Veterans' Health Research. Journal of General Internal Medicine. 2006;21:S82-S92. [pmid: 16637952].
4 Bean-Mayberry B, et al., editors. Systematic Review of Women Veterans Health Research 2004-2008. V. HSR&D, editor. 2010. Evidence Synthesis Program. Washington DC.
5 Ngo AD, et al. Association between Agent Orange and birth defects: systematic review and meta-analysis. Int J Epidemiol. 2006;35(5):1220-30. [pmid: 16543362].
6 Golomb BA. Acetylcholinesterase inhibitors and Gulf War illnesses. Proc Natl Acad Sci U S A. 2008;105(11):4295-300. [pmid: 18332428].
7 Araneta MR, et al. Conception and pregnancy during the Persian Gulf War: the risk to women veterans. Ann Epidemiol. 2004;14(2):109-16. [pmid: 15018883].
8 Pierce PF. Physical and emotional health of Gulf War veteran women. Aviat Space Environ Med. 1997;68(4):317-21. [pmid: 9096828].
9 Kang HK, et al. Pregnancy outcomes among U.S. women Vietnam veterans. Am J Ind Med. 2000;38(4):447-54. [pmid: 10982986].
10 Kang HK, et al. Prevalence of gynecologic cancers among female Vietnam veterans. J Occup Environ Med. 2000;42(11):1121-7. [pmid: 11094792].
11 Langlois PH, et al. Birth defects and military service since 1990. Mil Med. 2009;174(2):170-6. [pmid: 19317198].
12 Araneta MR, et al. Birth defects prevalence among infants of Persian Gulf War veterans born in Hawaii, 1989-1993. Teratology. 2000;62(4):195-204. [pmid: 10992261].
13 Araneta MR, et al. Prevalence of birth defects among infants of Gulf War veterans in Arkansas, Arizona, California, Georgia, Hawaii, and Iowa, 1989-1993. Birth Defects Res A Clin Mol Teratol. 2003;67(4):246-60. [pmid: 12854660].
14 Cowan DN, et al. The risk of birth defects among children of Persian Gulf War veterans. N Engl J Med. 1997;336(23):1650-6. [pmid: 9171068].
15 Gilhooly PE, et al. Chronic fatigue and sexual dysfunction in female Gulf War veterans. J Sex Marital Ther. 2001;27(5):483-7. [pmid: 11554210].
16 Kang H, et al. Pregnancy outcomes among U.S. Gulf War veterans: a population-based survey of 30,000 veterans. Ann Epidemiol. 2001;11(7):504-11. [pmid: 11557183].
17 Murphy F, et al. Women in the Persian Gulf War: health care implications for active duty troops and veterans. Mil Med. 1997;162(10):656-60. [pmid: 9339076].
18 Penman AD, Tarver RS, Currier MM. No evidence of increase in birth defects and health problems among children born to Persian Gulf War Veterans in Mississippi. Mil Med. 1996;161(1):1-6. [pmid: 11082741].
19 Wells TS, et al. Self-reported reproductive outcomes among male and female 1991 Gulf War era US military veterans. Matern Child Health J. 2006;10(6):501-10. [pmid: 16832610].
20 Werler MM, Sheehan JE, Mitchell AA. Gulf War veterans and hemifacial microsomia. Birth Defects Res A Clin Mol Teratol. 2005;73(1):50-2. [pmid: 15602762].
21 Wittich AC. Gynecologic evaluation of the first female soldiers enrolled in the Gulf War Comprehensive Clinical Evaluation Program at Tripler Army Medical Center. Mil Med. 1996;161(11):635-7. [pmid: 8961714].
22 Zivin K, et al. Suicide mortality among individuals receiving treatment for depression in the Veterans Affairs health system: associations with patient and treatment setting characteristics. Am J Public Health. 2007;97(12):2193-8. [pmid: 17971541].
23 Kaplan MS, McFarland BH, Huguet N. Firearm suicide among veterans in the general population: findings from the national violent death reporting system. J Trauma. 2009;67(3):503-7. [pmid: 19741391].
24 McCarthy JF, et al. Suicide mortality among patients receiving care in the veterans health administration health system. Am J Epidemiol. 2009;169(8):1033-8. [pmid: 19251753].
25 Wells TS, et al. A prospective study of depression following combat deployment in support of the wars in Iraq and Afghanistan. Am J Public Health. 2010;100(1):90-9. [pmid: 19910353].
26 Owens GP, Herrera CJ, Whitesell AA. A preliminary investigation of mental health needs and barriers to mental health care for female veterans of Iraq and Afghanistan. Traumatology. 2009;15(2):31-37.
27 Chatterjee S, et al. Gender differences in veterans health administration mental health service use: effects of age and psychiatric diagnosis. Womens Health Issues. 2009;19(3):176-84. [pmid: 19447322].
28 Cohen BE, et al. Mental health diagnoses and utilization of VA non-mental health medical services among returning Iraq and Afghanistan veterans. J Gen Intern Med. 2010;25(1):18-24. [pmid: 19787409].
29 Scott JN. Diagnosis and outcome of psychiatric referrals to the Field Mental Health Team, 202 Field Hospital, Op Telic I. J R Army Med Corps. 2005;151(2):95-100. [pmid: 16097114].
30 Wojcik BE, Akhtar FZ, Hassell LH. Hospital admissions related to mental disorders in U.S. Army soldiers in Iraq and Afghanistan. Mil Med. 2009;174(10):1010-8. [pmid: 19891211].
31 Rundell JR. Demographics of and diagnoses in Operation Enduring Freedom and Operation Iraqi Freedom personnel who were psychiatrically evacuated from the theater of operations. Gen Hosp Psychiatry. 2006;28(4):352-6. [pmid: 16814636].
32 Seal KH, et al. Trends and risk factors for mental health diagnoses among Iraq and Afghanistan veterans using Department of Veterans Affairs health care, 2002–2008. American Journal of Public Health. 2009;99(9):1651-1658. [pmid: 19608954].
33 Baker DG, et al. Trauma exposure, branch of service, and physical injury in relation to mental health among U.S. veterans returning from Iraq and Afghanistan. Mil Med. 2009;174(8):773-8. [pmid: 19743729].
34 Street AE, Vogt D, Dutra L. A new generation of women veterans: stressors faced by women deployed to Iraq and Afghanistan. Clin Psychol Rev. 2009;29(8):685-94. [pmid: 19766368].
35 Seal KH, et al. VA mental health services utilization in Iraq and Afghanistan veterans in the first year of receiving new mental health diagnoses. J Trauma Stress. 2010;23(1):5-16. [pmid: 20146392].
36 LaVela SL, et al. Geographical proximity and health care utilization in veterans with SCI&D in the USA. Soc Sci Med. 2004;59(11):2387-99. [pmid: 15450711].
37 Loney TG. The relationship between physical and occupational therapy intensity and rehabilitation outcomes of traumatic brain injury: a comparison of war wounded to non-war wounded persons. TUI University. 2007:163.
38 Bell RS, et al. Military traumatic brain and spinal column injury: a 5-year study of the impact blast and other military grade weaponry on the central nervous system. J Trauma. 2009;66(4 Suppl):S104-11. [pmid: 19359953].
39 Benda B. A Study of Substance Abuse, Traumata, and Social Support Systems Among Homeless Veterans. Journal of Human Behavior in the Social Environment. 2005;12(1):59-82. 2005. 12(q): p. 59-82.
40 Hawkins EJ, et al. Recognition and management of alcohol misuse in OEF/OIF and other veterans in the VA: a cross-sectional study. Drug Alcohol Depend. 2010;109(1-3):147-53. [pmid: 20167440].
41 Nunnink SE, et al. Female veterans of the OEF/OIF conflict: concordance of PTSD symptoms and substance misuse. Addict Behav. 2010;35(7):655-9. [pmid: 20378259].
42 Katz LS, et al. Post-Deployment Readjustment Inventory: reliability, validity, and gender differences. Military Psychology. 2010;22(1):41-56.
43 Moore KR. Predictors of self-reported change in health status among military personnel returning from deployment. Dissertation Abstracts International: Section B: The Sciences and Engineering S2- Dissertation Abstracts International. 2009;70(3-B):1626.
44 Fitzgerald CE. Improving nurse practitioner assessment of woman veterans. J Am Acad Nurse Pract. 2010;22(7):339-45. [pmid: 20590954].
45 Adler AB, et al. The impact of deployment length and experience on the well-being of male and female soldiers. J Occup Health Psychol. 2005;10:121-37. [pmid: 15826223].
46 Duggal M, et al. Comparison of outpatient health care utilization among returning women and men Veterans from Afghanistan and Iraq. BMC Health Serv Res. 2010;10:175. [pmid: 20565985].
47 Haskell SG, et al. Pain among Veterans of Operations Enduring Freedom and Iraqi Freedom: do women and men differ?. Pain Med. 2009;10(7):1167-73. [pmid: 19818028].
48 Jacobson IG, et al. Disordered eating and weight changes after deployment: longitudinal assessment of a large US military cohort. Am J Epidemiol. 2009;169(4):415-27. [pmid: 19193718].
49 Kelly MM, et al. Effects of Military Trauma Exposure on Women Veterans' Use and Perceptions of Veteran Health Administration Care. Journal of General Internal Medicine. 2008;23(6):741-747. [pmid: 18414956].
50 Fontana A, Rosenheck R. Treatment-seeking veterans of Iraq and Afghanistan: comparison with veterans of previous wars. J Nerv Ment Dis. 2008;196(7):513-21. [pmid: 18626291].
51 Zouris JM, Wade AL, Magno CP. Injury and illness casualty distributions among U.S. Army and Marine Corps personnel during Operation Iraqi Freedom. Mil Med. 2008;173(3):247-52. [pmid: 18419026].
52 Klausner AP, et al. The influence of psychiatric comorbidities and sexual trauma on lower urinary tract symptoms in female veterans. J Urol. 2009;182(6):2785-90. [pmid: 19850303].
53 LaVela S, et al. Disease Prevalence and Use of Preventive Services: Comparison of Female Veterans in General and Those with Spinal Cord Injuries and Disorders. MS. Journal of Women's Health. 2006.
54 Sherman SE, et al. Gender differences in smoking cessation services received among veterans. Womens Health Issues. 2005;15(3):126-33. [pmid: 15894198].
55 Stecker T, et al. Characteristics of women seeking intensive outpatient substance use treatment in the VA. J Womens Health (Larchmt). 2007;16(10):1478-84. [pmid: 18062763].