# KEY QUESTION 2 EVIDENCE TABLE

Author | Sample Characteristics | Sample Size | Design/Objective | Main Measures | Main Findings
Adler; 2005^45^ | U.S. female and male soldiers in non-combat arms units deployed on a NATO peacekeeping mission to the Bosnia area of operations that included Hungary, Bosnia-Herzegovina, and Croatia | Females 1,225 Males 2,114 | Observational; To examine the effects of stressor duration (deployment length) and stressor novelty (no prior deployment experience) on the psychological health of male and female military personnel returning from a peacekeeping deployment | Correlations between demographics, deployment experience, and dependent variables by gender; length of deployment and mean scale score of depressive and posttraumatic stress symptoms by gender; deployment experience and mean scale score of depressive and posttraumatic stress symptoms by gender | Longer deployments and 1^st^-time deployments were associated with an increase in distress scores. However, the relationship between deployment length and increased distress was found only for male soldiers.
Baker; 2009^33^ | Newly registered OEF/OIF Veterans and reservists, who consecutively enrolled for general care in the VA San Diego Healthcare System and completed a battery of questionnaires between April and October 2006 | 339 | Observational; To more comprehensively characterize the OEF/ OIF mental health concerns, examining the relationship between demographic factors, military service characteristics, combat-related injury, and mental health symptoms | Demographic and military service-related characteristics, mental health caseness, predictors of PTSD | - A minority (36%) did not screen positive for mental health symptoms; the remainder met threshold for caseness of PTSD, depression, or substance and alcohol abuse.; - Using a hierarchical logistic regression model, gender, age, race, and rank were not significantly related to PTSD caseness, whereas most recent branch of service and report of injury during combat were.; - Follow-up analyses revealed that trauma history and combat exposure varied by branch of service.
Bell; 2009^38^ | Inpatient admissions to 2 military hospitals over a 5 year period from a closed or penetrating head trauma suffered during combat operations in Iraq | Females 7 Males 401 | Observational; To describe a military hospital experience with severe closed and penetrating central nervous system trauma associated with conventional and unconventional warfare | Primary measures include type of injury, mechanisms, initial Glasgow coma scale (GCS), discharge GCS score, admission injury severity score (ISS), total intensive care unit (ICU) days, Glasgow Outcome Scale scores at discharge, 6 months, and 1-2 years | Most head injuries were male (98%), and most sustained penetrating brain injury with explosive blast accounting for the predominant mechanism of injury. The presence of CSF leak, vascular injury, and penetrating trauma resulted in higher ISS levels and ICU stays. (No gender specific results are reported.)
Benda; 2005^39^ | Convenience sample of all homeless female Veterans that entered an inpatient VA domiciliary program for substance abuse in a 3-year period. Systematic random sample of homeless men that entered program during same period. | Females 310 Males 315 | Observational; (1) to study gender differences in predictors of readmission to inpatient drug treatment among homeless Veterans because VA medical centers currently do not have services that are designed specifically for women; (2) are abuses at different stages of life span, combat exposure, and recent traumatic events commensurate predictors, do employment, housing, family or friend relationships and spirituality mediate (3) or moderate (4) relationships between trauma and relapse. | Re-admission to inpatient drug treatment in a two-year follow-up | Sexual and physical abuse in childhood or during active duty in the military and during the past 2 years were most potent predictors of readmission for women than men. Women's readmission was heightened by increases in depression, suicidal thoughts, and traumatic events. Women's readmission was lessened by greater family, friend, church or other support.; - Men's readmission increased with greater substance abuse, aggression, and cognitive impairment. Men's readmission decreases with employment stability and job satisfaction.
Chatterjee; 2009^27^ | National sample of Veterans with at least 1 outpatient visit in the VHA in FY99 associated with a mental health or substance abuse (SA) diagnosis | 782,789 | Observational; To compare gender differences in mental health disease burden and outpatient mental health utilization among Veterans utilizing Veterans Health Administration (VHA) mental health services | Odds of utilizing mental health and specialty mental health services by gender, age, and diagnostic category | - Younger women Veterans (<35 years old) were significantly less likely and older women (≥35) more likely to use any mental health services in comparison with their male counterparts.; - Similar findings were observed for younger women diagnosed with SA or mood and anxiety disorders, but not among Veterans with PTSD or bipolar and psychotic disorders, among whom there were no gender or age differences.; - In the case of specialized services for SA or PTSD, women younger than 55 with SA or PTSD were significantly less likely to use services than men.; - Women Veterans underutilized specialty mental health services in relation to men but receipt of mental health care overall in FY99 varied by age and diagnosis.
Cohen; 2009^28^ | National sample of Veterans newly utilizing VA healthcare between October 7, 2001 and March 31, 2007, followed until March 31, 2008 | 249,440 | Observational; To compare utilization across three groups of Iraq and Afghanistan Veterans: those without mental disorders, those with mental disorders other than PTSD, and those with PTSD | Variations in utilization of VA non-mental health services by mental health diagnoses | - Veterans with mental disorders had 42-146% greater utilization than those without mental disorders, depending on the service category (all p<0.001).; - Those with PTSD had the highest utilization in all categories: 71-170% greater utilization than those without mental disorders (all p< 0.001).; - In adjusted analyses, compared with Veterans without mental disorders, those with mental disorders other than PTSD had 55% higher utilization of all non-mental health outpatient services; those with PTSD had 91% higher utilization.; - Female sex and lower rank were also independently associated with greater utilization.
Duggal; 2010^46^ | Sample of female and male Operation Enduring Freedom (OEF) and Operation Iraqi Freedom (OIF) Veterans seeking healthcare services in the VA system | Females 240 Males 1,380 | Observational; To examine gender differences in the utilization of VA outpatient health care services | Outpatient VA service use included basic care (e.g., primary care, mental health, or specialty care). Initiation of care was defined as one visit or more to outpatient care after return from deployment and intensity of utilization was defined as the total number of outpatient visits during the study period. | Women were more likely to be younger, single, and non-white compared to men. Women were more likely to use outpatient care services (OR 1.47, 95% CI 1.09, 1.98), but once initiated, frequency of visits over time did not differ by gender (incident rate ratio [IRR] 1.07, 95% CI 0.90, 1.27).
Fitzgerald; 2010^44^ | Clinical guide to use screening tools for post traumatic stress disorder, traumatic brain injury, and military sexual trauma in the civilian setting | N/A | Clinical Practice Guideline; To provide nurse practitioners with a brief screening tools to be used during routine office visits to assist with accurate identification of post military health concerns | Not applicable | Potential benefits include more effective and comprehensive care to a growing female population with a history of military service seen for routine care. Brief screening instruments can help providers formulate accurate diagnoses of service related conditions with appropriate treatment and referral.
Fontana; 2008^50^ | Administrative sample of female and male Veterans in VA Northeast Program of Evaluation Center (NEPEC) database who sought treatment from a VA specialized program for PTSD and served in a war zone during only 1 of 3 recent wars | Total 36,413 (Sex not specified) | Observational; To compare current Iraq/ Afghanistan Veterans with 4 samples of outpatient and inpatient Persian Gulf and Vietnam Veterans | Socio-demographic characteristics, traumatic exposures (i.e., receiving hostile/friendly fire, participating in atrocities, and witnessing atrocities without participating), and clinical status including | Recent Iraq/ Afghanistan Veterans differed most notably from Vietnam Veterans by being younger, more likely to be female, less likely to be married or separated/divorced, more often working, less likely to report exposure to atrocities in military. Iraq/Afghanistan Veterans less often diagnosed with substance abuse disorders, manifested more violent behaviors, and had lower rates of VA disability compensation because of PTSD.
Haskell; 2009^47^ | National sample of Veterans from OEF/OIF roster from Defense Manpower Data Center containing all personnel discharged from US Military between October 1, 2001 to November 30, 2007 who enrolled for VA services or received VA care before January 1, 2008 | Females 18,481 Males 134,731 | Observational; To evaluate sex differences in the prevalence, severity, and persistence of pain among OEF/ OIF Veterans seen at VA outpatient clinic visits during the year after returning from deployment | Measures included pain numeric rating scores recorded at all outpatient visits, defined moderate to severe pain as >/= 4 rating, persistent pain defined as 3 or more pain scores >/= 4 recorded in at least 3 different months, ICD-9 codes for diagnoses of PTSD or depression if codes occurred on two or more outpatient visits, and demographic data | No significant difference was present for the probability of pain assessment by sex in bivariate and regression analysis (RR 0.98, 95%CI 0.96, 1.00). Female Veterans were less likely to report any pain compared to male (RR 0.89, 95%CI 0.86, 0.92). Among those with pain, female Veterans were more likely to report moderate-severe pain (RR 1.05, 95%CI 1.01, 1.09) and less likely to have persistent pain (RR 0.90, 95%CI 0.81, 0.99). When stratified by diagnosis, Veterans with depression or PTSD were more likely to be assessed for pain (p<.0001). However, there was no significant difference in the proportion of Veterans assessed for pain by sex in those with PTSD and depression (p>.05 in both cases).
Hawkins; 2010^40^ | National sample of Veterans in VA screened for alcohol use between October 1, 2006, and September 30, 2007, and under age 55 | Females 2,009 Males 10,083 | Observational; To evaluate the recognition and management of alcohol misuse in OEF/OIF Veterans enrolled in the VA system | Alcohol Use Disorders Identification Test Consumptions questions (AUDIT-C 10 question); military service information; documentation of brief intervention, referral, and completed referral for treatment | Age-specific and total prevalence of alcohol misused was higher for younger OEF/OIF men vs. non OEF/ OIF men. Rates of alcohol misuse were lower in both OEF/OIF and non OEF/OIF women. No significant difference was observed in the prevalence of alcohol misuse between OEF/OIF and non OEF/OIF women.
Jacobson; 2009^48^ | Population based sample of randomly selected military service members on rosters as of October 2000 from Millennium Cohort Study | Total 42,174 (Sex not specified) | Observational; To investigate disordered eating levels before and after deployment to determine the prospective association between stressful life events and the development of eating disorders | Disordered eating from 8 question survey from the Patient Health Questionnaire, weight change from baseline to follow up by self-report, demographics and military data | Women deployed with combat exposures were 1.78 times more likely to develop disordered eating (95%CI 1.02, 3.11) and 2.35 times more likely to lose an extreme amount of weight (95%CI 1.17, 4.70).
Kaplan; 2009^23^ | Suicide decedents aged 18 years and older from the combined 2003 to 2006 National Violent Death Reporting System | 28,534 | Observational; To examine the rate, prevalence, and relative odds of firearm use among Veteran suicide decedents in the general population | Total and firearm specific suicide rates by gender, Veteran status, and age groups | - Across the age groups, male and female Veterans had higher firearm suicide rates than non-Veterans.; - Among males and females, younger Veterans (18-34 years) had the highest firearm and total suicide rates.; - The male and female Veteran suicide decedents were, respectively, 1.3 and 1.6 times more likely to use firearms relative to non-Veterans after adjusting for age, marital status, race, and region of residence.; - Although violent death and use of firearms are generally associated with men, the results reported here suggest that firearms among female Veterans deserve particular attention among health professional within and outside the Veterans Affairs system.
Katz; 2010^42^ | Sample of post-deployed service members from OEF/ OIF duty | Females 32 Males 183 | Observational; To gather psychometric information on the newly developed Post-Deployment Readjustment Inventory (PDRI); validity testing | PDRI global scale and 6 subscales, General information form, Brief Symptom Inventory (BSI), Posttraumatic Checklist-Military version (PCL-M), demographics, and 5 items assessing exposure to war stressors: MST; being injured; and witnessing others injured or killed | The PDRI was highly correlated with the BSI, the PCL-M, and the items for substance abuse. Exposure to war events, scores of readjustment and symptoms were compared across gender. Overall MANOVA was not significant. However, they differed on type of exposure. Women reported a higher rate of MST than men, and men reported higher rate of witnessing others injured or killed than women.
Kelly; 2008^49^ | National, cross-sectional sample of female Veterans from the National Registry of Women Veterans stratified by age group, period of service, and race (black and non-black) | Females 1,496 | Observational; To investigate the effects of military sexual assault and combat exposure on women Veterans' use of Veterans Health Administration (VHA) services and perceptions of VHA care. | Military sexual assault history, combat exposure, use of VHA services, satisfaction with VHA services | Women Veterans with histories of military sexual assault reported more use of VHA services, but less satisfaction, poorer perceptions of VHA facilities and staff, and more problems with VHA services compared to women Veterans without histories of sexual assault. Combat exposure was related to more problems with VHA staff, although few other differences were observed for women with and without histories of combat exposure.
Klausner; 2009^52^ | Sample of women referred to a specialized lower urinary tract symptom clinic compared to women in a primary care clinic in a VA medical center | Females 1,298 | Observational; To characterize the association of psychiatric co-morbidities and sexual trauma with lower urinary tract symptoms (LUTS) | Survey items completed included the Incontinence Impact Questionnaire-7 to assess quality of life and Urogenital Distress Inventory -6 to assess symptoms, sexual trauma screening, pregnancy and birth histories, and psychiatric co-morbidities. | Women referred for LUTS evaluations had higher rates of psychiatric co-morbidities (64.5% vs. 25.9%, p<.001) and sexual trauma (49.6% vs. 20.1%, p<.001) compared to women in primary care. Stepwise multivariate regression demonstrated that higher UDI-6 scores associated with age<50 and history of miscarriage, while higher IIG-7 scores associated with psychiatric co-morbidities and history of miscarriage.
LaVela; 2006^53^ | Female Veteran data from a national cross-sectional survey mailed to Paralyzed Veterans of America (PVA) members for the SCI&D group and data from the CDC 2003 Behavioral Risk Factor Surveillance System (BRFSS) survey for the non-SCI&D comparison group | Females 593 | Observational; To compare disease prevalence and preventive service use among female Veterans in general and those with spinal cord injuries and disorders (SCI&D) | Disease/condition prevalence (asthma, diabetes, myocardial infarction, stroke, coronary heart disease, high blood pressure, high cholesterol, tooth decay/gum disease, injuries), health status (general health, physical and mental health), and use of preventive services (cholesterol check, dental care, influenza and pneumonia vaccinations, colon screening, breast and cervical cancer screening) among women Veterans with and without SCI&D | Female Veterans with SCI&D were similar in age and race but were better educated and less likely to be employed than female Veterans in general. Coronary heart disease (CHD) prevalence was higher in those with SCI&D (17% vs. 8%, p < 0.0001). Health status was lower in SCI&D (27%) than in general female Veterans (41%), p = 0.002. Fewer women with SCI&D, than female Veterans in general reported having received recommended dental care (56% vs. 69%, p=0.004), colon screening in prior 5 years (59% vs. 72%, p = 0.023) or prior 10 years (67% vs. 92%, p < 0.0001), mammogram (84% vs. 91%, p = 0.019), and Pap smear (88% vs. 98%, p < 0.0001). There were no differences in receipt of respiratory vaccinations or cholesterol screening.
LaVela; 2004^36^ | Veterans with spinal cord injuries and disorders (SCI&D) identified with the Spinal Cord Dysfunction Registry (SCD-R) for 2001 | Total 8,983 98% male | Observational; To describe inpatient and outpatient health care utilization of Veterans with SCI&D; to determine whether health care utilization patterns differ based on residing longer or shorter distances from sources of care; to determine if VA facility closest to patient is bypassed in order to receive care at another VA facility | Utilization defined as any inpatient or outpatient health care services, history of illness (defined as 1 hospitalization in the prior year), travel distance between the zip code center to the VA facility used, and travel distance to the nearest VA | Patients used OP services less frequently when VA facilities were farther away from their residences. Male Veterans with SCI&D were less likely than females Veterans to utilize OP care (p<.0000). Being male reduced the number of OP visits by 27%.
Loney; 2007^37^ | Sample of soldiers with traumatic brain injury (war wounded and non war wounded) admitted to one VA medical center for physical and occupational therapy between January 1, 2004 and December 31, 2005 | Females 10 Males 109 | Dissertation/Observational; To identify which variables are most associated with therapy intensity and functional clinical outcomes in war wounded traumatic brain injury soldiers from OEF/OIF | Therapy intensity was measured in terms of duration, functional independent measure (FIM), FIM change and FIM efficiency, Severity of injury and TBI polytrauma/blast co-morbidities | War wounded TBI patients had lower admission FIM scores (M = 77.09, SD = 41.55), admission Mobility FIM scores (M = 21.66, SD = 12.85) and spent longer time between initial injury and admission to rehabilitation (M = 92.81, SD = 110.80) than the non-war wounded admission FIM scores (M = 68.18, SD = 32.23), admission Mobility FIM scores (M = 19.00, SD = 10.78), and shorter time between initial injury and admission to rehabilitation (M = 57.58, SD = 63.91). (No specific findings were given by gender. Gender was used in models.)
McCarthy; 2009^24^ | All Veterans with inpatient or outpatient services utilization in any VHA facility during fiscal year 2000 or fiscal year 2001 using data from the VHA's National Patient Care Database | 4,670,968 | Observational; To examine suicide rates among VHA patients and compare them with rates in the general population | Mortality ratios for suicide risks among VHA patients for age and gender subgroups compared with those in the general US population | - Overall, for men and women combined, suicide risks among VHA patients were 66% higher than those observed in the general US population.; - VHA rates were 43.13/100,000 person-years for men and 10.41/100,000 person-years for women.; - For male patients, the age-adjusted standardized mortality ratio was 1.66; for females, it was 1.87.; - Male patients aged 30-79 years had increased risks relative to men in the general population; standardized mortality ratios ranged from 2.56 (ages 30-39 years) to 1.33 (ages 70-79 years).; - Female patients aged 40-59 years had greater risks than did women in the general population, with standardized mortality ratios of 2.15 (ages 40-49) and 2.36 (ages 50-5 years).
Moore; 2009^43^ | Cohort of service members who repeated their PDHA from deployments to OIF/OEF in 2004-2005 | Females 1,061 Males 7,777 | Dissertation/Observational; To identify the health concerns and symptoms that changed, during and after deployment and predicted repeat PDHA | Post Deployment Health Assessment (PDHA), and demographics | Results yielded significant values for age, gender, service, and length of deployment with changes in health concerns. Females were less likely than males to report health changes (OR 0.542, 95%CI 0.470, 0.626). There was a significant correlation between service members that were female (r=.26, p=.013); had shorter deployments (r=-.050, p=.000); and were older (r=.28, p=.009) for increased changes in their second PDHA. Change in health symptoms occurred for 12 of 19 symptoms measured.
Nunnink; 2010^41^ | Newly enrolling female Veterans in 1 southern California VA Medical Center | Females 36 | Observational; To examine the rates of co-morbid PTSD and substance abuse in an all-female OEF/ OIF Veteran sample, and to investigate the differences in substance abuse in women screening positive vs. screening negative for PTSD | Alcohol Use Disorders Identification Test (AUDIT 10) for alcohol screening, Drug Abuse Screening Test (DAST), the Davidson Trauma Scale (DTS) to measure PTSD symptomatology, demographics, discharge type, and screening items for exposure to combat and problems with alcohol | Thirty-one percent (11) of this small sample of OEF/ OIF female Veterans screened positive for PTSD symptoms, 47% (17) screened positive for high-risk drinking and 6% (2) screened positive for drug abuse. Alcohol and drug misuse were both good predictors of PTSD symptoms. Increase awareness and screening for both PTSD and alcohol problems in female Veterans is paramount.
Owens; 2009^26^ | Female Veterans of Iraq and Afghanistan who completed an online survey for the study | 50 | Observational; To examine the mental health needs and barriers to mental health service use specifically for female Veterans of the wars in Iraq and Afghanistan | Combat exposure and mental health symptoms, mental health services utilization, comparisons between treatment seeker and non-treatment seekers, barriers to seeking mental health services in the VA system | - The most frequently reported concerns for which participants indicated they needed counseling were depression, relationship issues, anxiety, and anger management.; - Although 78% of respondents reported that they felt they needed treatment in the past year, 42% of these individuals indicated that they did not seek counseling.; - Two commonly reported barriers to seeking mental health services in the VA were long waiting periods for appointments and prior bad experiences.; - Mental health concerns and symptoms of returning female Veterans indicate the need for treatment, but a significant gap remains in the self-reported need for assistance and seeking of services.
Rundell; 2006^31^ | Records of consecutive OEF/OIF patients who were medially evacuated to the Landstuhl Regional Medical Center (LRMC) in Germany from the theater of operations for primarily psychiatric reasons between November 4, 2001, and July 30, 2004 | 1,264 | Descriptive; To characterize the demographic and clinical information of OEF and OIF military personnel who were psychiatrically evacuated from the theater of operations | Demographic and administrative characteristics, psychiatric diagnoses | - When compared with all returned OEF/OIF Veterans, psychiatric evacuees were more likely to be: female, under the age of 31 years, African-American or Hispanic, enlisted and National Guard/Reserve.; - Over 80% of patients were evacuated during the first 6 months, compared with 17% during the second 6 months of deployment.; - The most common diagnostic categories were adjustment disorders (37.6%), mood disorders (22.1%), personality disorders (15.7%) and anxiety disorders (15.4%); 16.5 % received no psychiatric diagnosis.; - Only 5% of evacuees returned to OEF/OIF duty.; - Almost half of evacuated patients received no diagnosis or no adjustment disorder diagnosis, suggesting clinical improvement since a decision for evacuation was made.
Seal; 2009^32^ | OIF and OEF Veterans who were first-time users of VA health care after their OIF and OEF military service from April 1, 2002 through March 31, 2008 | 289,328 | Observational; To investigate longitudinal trends and risk factors for mental health diagnoses among Iraq and Afghanistan Veterans | Prevalence of mental health diagnoses | - Of 289,328 Iraq and Afghanistan Veterans, 106,726 (36.9%) received mental health diagnoses; 62,929 (21.8%) were diagnosed with PTSD and 50,432 (17.4%) with depression.; - Adjusted 2-year prevalence rates of PTSD increased 4 to 7 times after the invasion of Iraq.; - Active duty Veterans younger than 25 years had higher rates of PTSD and alcohol and drug use disorder diagnoses compared with active duty Veterans older than 40 years (adjusted relative risk = 2.0 and 4.9, respectively).; - Women were at higher risk for depression than were men, but men had over twice the risk for drug use disorders.; - Greater combat exposure was associated with higher risk for PTSD.
Seal; 2010^35^ | National subgroup of OEF and OIF Veterans who received VA health care services between April 1, 2002 and March 31, 2008 | 84,972 | Observational; To evaluate OEF and OIF Veterans' utilization of VA mental health services, looking at 3 main factors: predisposing, enabling, and need factors | VA mental health services utilization and the intensity of VA mental health services utilization | - Of 49,425 Veterans with newly diagnosed PTSD, only 9.5% attended 9 or more VA mental health sessions in 15 weeks or less in the first year of diagnosis.; - Engagement in 9 or more VA treatment sessions for PTSD within 15 weeks varied by predisposing variables (age and gender), enabling variables (clinic of first mental health diagnosis and distance from VA facility), and need (type and complexity of mental health diagnoses).; - Only a minority of Iraq and Afghanistan Veterans with new PTSD diagnoses received a recommended number and intensity of VA mental health treatment sessions within the first year of diagnosis.
Sherman; 2005^54^ | Sample Veterans (and their female partners) who served in the Vietnam War, had a diagnosis of PTSD and service-connected disability for PTSD, participated in the PTSD program, and current cohabitation with a female partner recruited from two VA medical centers | Females 72 | Observational; To perform an initial needs assessment of partners of Vietnam Veterans with combat-related post-traumatic stress disorder (PTSD) and to assess the partners' current rates of treatment use. | Partner treatment experiences and ratings of treatment needs; partners' assessment of her need for individual treatment and the partner's appraisal of family treatment being extremely important (yes/ no). | Although large majorities of partners rated individual (64%) and family therapy (78%) to help cope with PTSD in the family as extremely or very important, only 28% had received any mental health care in the previous six months. Significant predictors of desire for individual treatment included partner's anxiety and patient-partner contact, and partner's age and severity of the patient's PTSD symptoms were significant predictors of family treatment. The most commonly requested service was a women-only group.
Stecker; 2007^55^ | VA national databases were used to identify Veterans receiving IOP substance use treatment, and Veterans with substance use disorders attending primary care but not in treatment. | Females 247 Males 8,082 | Observational; To investigate gender differences among Veterans receiving intensive outpatient (IOP) substance use treatment in a national VA sample and to compare women attending IOP with women with substance use disorders in VA primary care. | Psychiatric and medical conditions that co-occur with substance use disorder | Stigma was portrayed as a major disadvantage to treatment seeking. Yet most participants indicated that people would be supportive of treatment seeking. Reducing symptoms was a major advantage to care. Barriers included pride, not being able to ask for help, and not being able to admit to having a problem.
Street; 2009^34^ | Literature review on gender-relevant issues among OEF/ OIF female Veterans | N/A | Systematic review/ meta-analysis; To highlight emerging issues relevant to the development of PTSD among women deployed to Iraq and Afghanistan | Combat experiences in Iraq and Afghanistan, sexual assault and sexual harassment, exposure to other interpersonal stressors, the role of premilitary and postmilitary interpersonal trauma, homecoming readjustment | Women are approximately twice as likely as their male counterparts to be diagnosed with PTSD. However, there are also indications that the gender-specific risk of PTSD differs substantially by type of traumatic event.
Wells; 2010^25^ | Participants in the first panel of Millennium Cohort Study 2001-2006 who completed baseline and follow-up questionnaires and met inclusion criteria | 40,219 | Observational; To investigate relations between deployment and new-onset depression among US service members recently deployed | Comparison of new-onset depression by deployment status and gender | - Deployed men and women with combat exposures had the highest onset of depression, followed by those not deployed and those deployed without combat exposure.; - Combat –deployed men and women were at increased risk for new-onset depression compared with nondeployed men and women (men: adjusted oddos ration [AOR]=1.32; 95% CI=1.13, 1.54; women: AOR=2.13; 95% CI=1.70, 2.65).; - Conversely, deployment without combat exposures led to decreased risk for new-onset depression compared with those who did not deploy (men: AOR=0.66; 95% CI=0.53, 0.83; women: AOR=0.65; 95% CI=0.47, 0.89).
Wojcik; 2010^30^ | All U.S. Army soldiers deployed from September 2001 (OEF) and September 2002 (OEF) through December 2004 | 473,964 | Observational; To examine the magnitude and characteristics of mental disorder hospitalizations among U.S. Army soldiers deployed in Iraq and Afghanistan through December 2004 | Relative risks of mental disorder admissions in OIF and in OEF, attempted suicide/self-inficted-related admissions | - There were a total of 1,948 psychiatric hospitalizations of deployed soldiers.; - The most common mental problems were mood, adjustment, anxiety disorders (including PTSD).; - Relative risk (RR) of mental disorders ranged from 1.6 to 3 for females and 2 to 6 for enlisted soldiers compared to their counterparts.; - Younger soldiers had 30-60% higher substance abuse disorders.; - Combat units in Iraq demonstrated higher risk of any mental disorder and anxiety problems compared to combat support units.; - Younger women had the highest incidence of attempted suicide/self-inflicted injuries.
Zivin; 2007^22^ | National sample from the VA's National Registry for Depression (NARDEP) from April 1, 1999 to September 30, 2004 | 807,694 | Observational; To report clinical and demographic factors associated with suicide among depressed Veterans in an attempt to determine what characteristics identified Veterans at high risk for suicide | Suicide, and association with patient age, race, gender, substance abuse diagnosis, diagnosis of PTSD, Hispanic ethnicity, treatment location, prior VA hospitalization, service connection, and baseline medical comorbidity. | - Of 807,694 Veterans meeting study criteria, 1683 (0.21%) committed suicide during follow-up.; - Increased suicide risks were observed among male, younger, and non-Hispanic White patients.; - Veterans without service-connected disabilities, with inpatient psychiatric hospitalizations in the year prior to their qualifying depression diagnosis, with comorbid substance use, and living in the southern or western United States were also at higher risk.; - Posttraumatic stress disorder (PTSD) with comorbid depression was associated with lower suicide rates, and younger depressed Veterans with PTSD had a higher suicide rate than did older depressed Veterans with PTSD.; - Unlike the general population, older and younger Veterans are more prone to suicide than are middle-aged Veterans.
Zouris; 2008^51^ | Review of hospitalization data from OIF for casualties monitored by TRANSCOM Regulating and Command and Control Evacuation system (TRAC2ES) and Joint Patient Tracking Application (JPTA) that monitors all branches of the US Armed Forces in theatre of operations | Females 1,305 Males 11,766 | Observational; To describe the distribution of evacuated wounded in action (WIA) and Disease and Nonbattle Injury (DNBI) casualties sustained during the Major Combat Phase (OIF-1) and the Support and Stability Phase (OIF-2) of OIF involving the US Army and Marines | Primary ICD-9 diagnoses, gender, service were obtained, and casualties were classified as WIA or DNBI, subcategories of ICD-9 diagnoses were also created | The majority of casualties were DNBI (75%), Army personnel (83.5%) and were male (90%). Disease and nonbattle injury ICD-9 distributions differed by gender. The proportion of nonbattle injuries was significantly higher among men. Subcategories more common among women than men included neoplasms, mental disorders, diseases of the blood, respiratory, and genitourinary symptoms.