# KEY QUESTION 1 EVIDENCE TABLE

Author | Sample Characteristics | Sample Size | Design/Objective | Main Measures | Main Findings
Araneta; 2000^12^ | Infants born to Gulf War Veterans (GWV) non-deployed Veterans (NDV) who were registered in Hawaii Birth Defects Program in 1989-1993. | 17,187 military infants of GWV and NDV in Hawaii were identified. | Compare prevalence of selected congenital anomalies between:; 1. GWV and NDV conceived before the war; 2. GWV and NDV conceived during or after war; 3. Prewar/postwar conceptions of GWV population-based study | 48 major birth defects prevalence among military births in Hawaii through the first year of life | Prevalence of 48 selected birth defects was similar in NDV and GWV groups in conceptions that happened before the war and conceptions during and after the Gulf war. Among GWV infants, the prevalence of 48 selected birth defects did not differ among prewar and postwar conceptions. Limitations: small numbers of case infants with birth defects- not enough statistical power for rare birth defects. Unable to evaluate role of maternal GWV exposure because small numbers of births in female GWV (165 births) in Hawaii.
Araneta; 2003^7^ | Deployment data and inpatient records from military hospitals. | 1,558 females | Compare reproductive outcomes of Gulf War with postwar conceptions of women deployed and non-deployed. | Adverse reproductive outcomes, spontaneous abortions, ectopic pregnancies | Gulf War exposed conceptions and non-deployed conceptions had similar outcomes. However, Gulf War Veterans postwar conceptions were at increased risk of ectopic pregnancies and spontaneous abortions.
Araneta; 2003^13^ | Infants born to Gulf War Veterans (GWV) non-deployed Veterans (NDV) who were registered in Arkansas, Arizona, California, Georgia, Hawaii and Iowa Birth Defects Program, a population-based birth defect registries, in 1989-1993 | 11,961 military infants of GWV and 33,052 military infants of NDV registered in Arkansas, Arizona, California, Georgia, Hawaii and Iowa were identified. | Determine prevalence of selected congenital anomalies between:; 1. GWV and NDV conceived before the war; 2. GWV and NDV conceived during or after war; 3. Prewar/postwar conceptions of GWV population-based study | 48 major birth defects prevalence among military births in Hawaii through the first year of life | Higher prevalence of tricuspid valve insufficiency, aortic valve stenosis, and renal agenesis or hypoplasia in infants conceived to post war GWV men. Higher prevalence of hypospadias in infants conceived postwar to female GWV. Above persisted after adjustment for known risk factors and population differences. No difference in risk for any of combined 48 selected defects by deployment status.
Cowan; 1997^14^ | Live births at 135 military hospitals 1991-1993 | GWV offspring; - 30.151 live births born to 29,468 male GWV; - 32,638 live births born to 31,646 male NDV; - 3,847 live births to 3722 women GWV; - 8,825 live births to 8494 women NDVW | To compare overall risk of birth defects among offspring of GWV to offspring of non deployed Veterans (NDV) | Occurrence of birth defects noted in the medical file. ICD-9-CM code related to congenital malformations | - No increase in birth defects among children of GWV.; - Prevalence of any birth defect was 7.45% for deployed Veterans and 7.59% for non-deployed Veterans (RR 0.98, 95% CI 0.93-1.03).; - No significant association between service in the Gulf War and prevalence of any birth defect for male Veterans (OR 0.97, 95% CI 0.91-1.03) or female Veterans (OR 1.07, 95% CI 0.94-1.22).; - The unadjusted OR for having an infant with severe birth defects was 1.03 (95% CI 0.92-1.15) for male active-duty Veterans, 0.92 (95% CI 0.71-1.20) for female active duty Veterans, and 1.00 (95% CI 0.90-1.10) for men and women combined.; - Limitation: military facilities only.
Gilhooly; 2001^15^ | Previously deployed female US Persian Gulf Veterans enrolled in New Jersey Persian Gulf War Research Center Study | 46 Female | Relationship between sexual dysfunction in female Gulf War Veterans | This study evaluated sexual female dysfunction in Veterans with and without chronic fatigue. | Chronic fatigue is one of the most chronic conditions reported by Gulf War Veterans. Includes 22 healthy subjects and 26 with fatigue. Female sexual dysfunction was reported by 10% of control and by 60% of those with fatigue (p value < .002). 19% vs 81% (p value < .001) decrease in libido.
Kang; 2000^9^ | U.S. women Veterans in the U.S. military during the period July 4, 1965 through March 28, 1973 | 8,280 US women Veterans (4140 deployed, 4140 not deployed) | Comparison of self-reported pregnancy outcomes among women Veterans who were deployed to Vietnam and those who were not | Risk of having children with moderate to severe birth defects was significantly elevated among Vietnam Veterans. | The risk of birth defects among index children was significantly associated with mother's military service in Vietnam.
Kang; 2000^10^ | U.S. women Veterans in the U.S. military during the period July 4, 1965 through March 28, 1973 | 4,140 Female | Structured telephone interview including history of gynecologic cancer | The association between the risk of GYN cancer and military service in Vietnam | Female Vietnam Veterans did not experience a higher prevalence of GYN cancer in the 30 years since the conflict.
Kang; 2001^16^ | Gulf War Veterans | 11,441 Gulf War Veterans and 9476 control subjects | Comparison of reproductive outcomes among US Gulf War Veterans and non-Gulf War Veterans | Miscarriages and birth defects | This survey suggests that female Gulf War Veterans report significantly higher rates of birth defects than do military control subjects.
Langlois; 2009^11^ | Population based Case control study – National Birth Defects Prevention Study (NBDPS) | Cases born Oct 1999 to Dec 2003. 150 cases and 3 exposed cases | Population based Case control study- National Birth Defects Prevention Study (NBDPS) | Association between cohorts and active duty birth over 30 major defects | - No statistically significant associations between maternal or paternal military service and elevated risk of selected birth defects.; - Of the 35 birth defects presented, 5 exhibited adjusted odds ratios above 1.50: hydrocephalus, atrioventricular septal defects, anomalous pulmonary venous return, heterotaxia, and omphalocele - though not statistically significant.; [image] None of the odds ratios 1.00 were statistically significant.; - Tricuspid atresia exhibited the highest crude odds ratio (2.03), but that decreased to 1.43 after adjustment for maternal age, race/ethnicity, and education.
Murphy; 1997^17^ | Female troops deployed to the Persian Gulf | 10,00 Female and 15,000 Male | Literature review and analysis of VA and DoD health registries to determine healthcare use and needs of female Veterans | Diagnoses and symptoms by gender | This article found female health care needs to be similar to those of their male counterparts, with the exception of gynecologic issues. More data is needed, especially for determining long-term health care needs after deployment.
Penman; 1996^18^ | Population based registries used to determine Live born and Stillborn children born after deployment to National Guard personnel in two units in southeast Mississippi from Dec 1993-May 1994 | 54 children 6 mothers were Veterans (including one family with both parents Veterans) | Data reviewed from 2 population based registries; 1. Metropolitan Atlanta Congenital Defects Program; 2. Centers for Disease Controls' Birth Defects Monitoring Program California Birth Defects Monitoring Program | Birth Defects Still Births Deaths | - The observed number of birth defects among was not greater than expected on the basis of population-based registries.; - 3 cases of major birth defects, 2 cases of minor birth defects, No stillbirths, no deaths.
Pierce; 1997^8^ | Female Veterans post Gulf War from the DoD Manpower Data Center | 525 Female | Conducted a survey to collect demographic data, as well as physical and mental health data | Multiple statistical analyses were used to describe women's physical/emotional health the two times point following the GW. | 525 women participated in the study following the war and again in a follow up study two years later (sampled from members of the Air Force: active, guard, or reserve). Measures included general physical health, gender specific health, “Gulf War Syndrome,” and PTSD. Multiple statistical analyses were used to describe women's physical and emotional health at two time points following the war. Deployed female Veterans reported significantly more general and gender specific health problems than did women who were not deployed in that conflict. Findings from this study suggest the need for further study concerning gynecological and reproductive health.
Wells; 2006^19^ | Deployed and non-deployed Gulf War era Veterans | 2,233 female, 2,159 male participants | Comparison of deployed and non-deployed Veterans surveyed on self-reported reproductive outcomes | Reproductive outcomes (birth weight, number of pregnancies) Adverse reproductive outcomes (ectopic pregnancies, stillbirths, miscarriages) | - No difference in number of pregnancies, birth weight of infants.; - Neither gender of deployed Gulf War Veterans significantly differed from non-deployed Veterans in adverse reproductive outcomes.
Werler; 2004^20^ | Cases from craniofacial clinics in 26 cities (US and Canada) and matched to 832 controls by pediatrician and child's age HFM cases ≤ 3 years old (born 1996-2002) | Birth year of cases to controls were 1996-2002. There were 232 cases and 832 controls. Four mothers and 30 fathers served in the military, and 10 control mothers and 100 control fathers also served in the military | Retrospective Case-control study Describe relationship between Hemifacial microsomia HFM) (Goldenhar syndrome) risk and parental military service (including Gulf War) | Measure Gulf War Service that occurred between 5 and 11 years before pregnancy Odds ratio of risk of multi adjusted odds ratio of HFM in those serving in the Gulf war for five to 11 years before pregnancy. Association of gulf or military service with HFM | - Mothers of 4 cases and 10 controls reported military service before and after pregnancy.; - Neither military service overall or Gulf War Service was associated with HFM risk. Odds ratio for any parental military service was elevated- but not statistically significant.; - Parental army service assoc with 2.4 fold increase of HFM- after adjusting for race, income, twin, and low body mass. (OR 2.4, 95% CI 1.4-4.2), parental GW army service (OR 2.8, 95% CI 0.8-9.6);; - Association with any parent served in the Gulf War was not increased (OR 0.8, 95% CI 0.3-2.3).
Wittich; 1996^21^ | Women enrolled in DoD Persian Gulf Illness Comprehensive Clinical Evaluation Program at Tripler Army Medical Center | 17 females, 16 served in Gulf War and 1 dependent of Gulf War Veteran | Description of the sample's treatments during the program and reproductive histories | N/A | Services and histories are described, with 8 Veterans experiencing gynecologic problems while serving in the Gulf, and 43% since returning in 1991. Six patients became pregnant after returning, with 1 patient suffering miscarriages.