# SEARCH STRATEGIES

REPRODUCTIVE (8/4/2010)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1966-8/4/2010

LANGUAGE:

English

SEARCH STRATEGY:

reproductive OR reproduction OR pregnan* OR birth* OR fertility OR infertility OR infertile OR menstrual OR menstruation OR menses OR urinary tract OR sexually transmitted OR hiv OR cervical OR ovarian OR genital OR gynecologic* OR “Congenital Abnormalities”[Mesh]

AND

veteran*[tiab] OR veteran*[mh] OR military personnel

AND

female* OR women* OR woman OR gender OR women's health

=======================================================================

OEF/OIF (8/2/2010)

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1990-8/2/2010

LANGUAGE:

English

SEARCH STRATEGY:

veteran*[tiab] OR veteran*[mh] OR military personnel

AND

female* OR women* OR woman OR gender OR women's health

AND

gulf war OR persian gulf OR “desert storm” OR iraq* OR afghanistan OR OEF OR OIF OR “enduring freedom” OR afghan

=======================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

PsycINFO – 1990-8/2/2010

LANGUAGE:

English

SEARCH STRATEGY:

veteran* OR military personnel

AND

female* OR women* OR woman OR gender

AND

gulf war OR persian gulf OR “desert storm” OR iraq* OR afghanistan OR OEF OR OIF OR “enduring freedom” OR afghan

Population Group: Female

Search modes - Phrase Searching (Boolean)

=======================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

CINAHL (Cumulative Index to Nursing & Allied Health Literature) – 1990-8/2/2010

LANGUAGE:

English

SEARCH STRATEGY:

veteran* OR military personnel

AND

female* OR women* OR woman OR gender

AND

gulf war OR persian gulf OR “desert storm” OR iraq* OR afghanistan OR OEF OR OIF OR “enduring freedom” OR afghan

Gender: Female

Search modes - Phrase Searching (Boolean)

=======================================================================

DATABASE SEARCHED & TIME PERIOD COVERED:

Social Science Abstracts – 1990-8/2/2010

LANGUAGE:

English

SEARCH STRATEGY:

veteran* OR military personnel

AND

female* OR women* OR woman OR gender

AND

gulf war OR persian gulf OR “desert storm” OR iraq* OR afghanistan OR OEF OR OIF OR “enduring freedom” OR afghan

Search modes - Phrase Searching (Boolean)