# SUMMARY AND DISCUSSION

This evidence map organizes and describes the broad field of research related to women Veterans' health published between 2008 and 2015. In the past 8 years, this literature base has grown and developed substantially. In 2010, Bean-Mayberry and colleagues published a systematic review of the women Veterans' health research completed between 2004 and 2008.^2^ Their review, presented at the 2010 VA Women's Health Services Research Conference, helped outline the existing knowledge gaps and develop directions for future research. In July-August 2011, Women's Health Issues devoted a supplemental issue (Health and Health Care of Women Veterans and Women in the Military: Research Informing Evidence-Based Practice and Policy, Volume 21-4S) to women Veterans' health.^442^ An article by Elizabeth Yano and colleagues summarized the outcomes of that conference and set forth an ambitious research agenda.^445^ The VA Women's Health Research Network has worked to support and advance this agenda. Whereas many independent researchers from both in and outside of VA contribute to the overall research base in this broad field, our analysis confirms a significant shift in topics and increase in research since 2011.

Our evidence map of the literature published between 2008 and 2015 reveals significant strides in many priority areas, several persistent limitations, and areas to consider moving forward.

## ADVANCES IN KEY RESEARCH PRIORITIES

The 2010 VA Women's Health Services Research Conference resulted in the development of a research agenda with 6 key topic areas, listed below:^445^

- Access to care and rural health
- Primary care and prevention
- Mental health
- Post-deployment health
- Complex chronic conditions/ long-term care and aging
- Reproductive health.

As described in the “Overview of Extracted Data,” we utilized an expanded, though parallel array of healthcare categories in creating this evidence map. A complete cross-walk between those categories and the key topic areas that comprise the 2010 Women's Health Services Research Agenda and can be found in Table 2. An additional overarching goal of the research agenda was to begin transitioning from observational studies to interventional research.^446^ Cross-agency partnerships and collaborations were sought to help expand financial and intellectual resources for women's health research.^445^

We observed advances in the following key research priorities (Table 14):

Table 14 Advances in Key Research Priorities

Research Priority Areas | | Notable Advances
Topics | Access to Care/Rural Health Post-deployment Health Reproductive Health | Increased number of publications
Topics | Primary Care Delivery Mental Health | More interventional research
Populations | OEF/OIF Veterans | New studies specific to Veterans of recent conflicts
Populations | LGBT Veterans | Increased articles New transgender focus
Populations | Racial & Ethnic Minorities | Increased articles with a minority focus Identification of minority women in 100% female studies
Populations | Homeless Veterans | Increased number of articles with some focused on Veterans of recent conflicts
Research Funding | DoD Funding Other Governmental Funding | Increasingly common sources of funding, including for RCT/CCTs

### Priority Topics

Of these 6 key topic areas, 4 (and a subsection of a fifth) have shown notable growth in the last 8 years. Three smaller topic areas – access to care and rural health, post-deployment health, and reproductive health – demonstrated a significant increase in the number of articles published, with total counts rising up to seven-fold from the first half of our review period to the second half. Studies in these areas were largely observational but included several qualitative studies and one large VA-funded RCT focused on post-deployment health.^413^ A fourth key topic area, mental health research, particularly that related to PTSD and MST, has not only grown in numbers, but has also recently begun to shift from entirely observational to include a few interventional studies. To that end, 4 new small to moderate-sized RCTs on PTSD and MST were published between 2013 and 2015. Notably, only one of those trials received VA funding and only 2 were multi-site VA studies. Within the broad area of primary care and prevention, the subsection of research specifically related to the organization and delivery of primary and comprehensive care for women Veterans (categorized under “Healthcare Organization and Delivery” for the purposes of this evidence map), has also advanced considerably in both publication numbers and scope, including several qualitative studies and an RCT.

### Priority Populations

Research addressing priority populations has also increased substantially over the past 8 years. Returning OEF/OIF Veterans have dramatically shifted the demographics of current US Veterans, particularly for women. Over one-fifth (22% or 95/440) of the articles included in this review specifically targeted Veterans from OEF/OIF/OND or the Persian Gulf conflicts. This encompassed nearly all (89% or 95/107) the articles that specified a period of service for included Veterans. Three-quarters of those studies (72/95 or 76%) were published since 2012, including 2 RCTs and 6 qualitative studies. Nearly one-quarter (23/95 or 24%) of the studies that targeted Veterans of recent or ongoing conflicts included only women.

One of the goals set forth in the 2010 VA Women's Health Services Research Agenda was to increase the knowledge base related to potentially vulnerable populations of women Veterans, including LGBT, racial and ethnic minority, and homeless Veterans. As noted above, most (86% or 12/14) of the observational studies concerning LGBT Veterans were published since 2012, including 4 studies of transgender Veterans and 6 multi-site VA studies. Over 70% (10/14 or 71%) were VA-funded.

Twelve observational articles particularly highlighted issues related to racial and ethnic minorities, 7 of which were VA-funded. Two-thirds of these (8/12) were published since 2012. Many studies (278/440 or 63%) reported race or ethnicity specifically for female study subjects, increasing the potential for secondary or subgroup analyses by race. Studies that included only women (which doubled in number during our review period from k = 61 the first 4 years to k = 126 the second 4 years) were far more likely to identify race and ethnicity for women study participants (164/187 or 88%). None of the qualitative studies, randomized trials, or secondary trial analyses we identified focused on issues related to race or ethnicity.

Research about homelessness has also increased substantially during this review period. We identified 12 studies focused on homelessness, including 3 specifically devoted to homeless OEF/OIF Veterans, as well as 7 studies in other topic areas that specifically addressed homeless participants. Most (14/19 or 74%) were published since 2012.

### Research Funding

Only a small proportion of studies reported non-VA governmental funding sources such as DoD or NIH. However, the number of studies funded by these sources rose steadily throughout the study period, from k = 8 (DoD) and k = 25 (other governmental agencies) in the first half of the review period, to k = 21 (DoD) and k = 40 (other governmental agencies) in the second half. Notably, these funding sources accounted for 4 of the 8 randomized trials we identified.

## SHORTFALLS AND LIMITATIONS OF THE LITERATURE

### Gaps within Specific Healthcare Topics

Despite the advances in 4 of 6 priority topic areas noted above, 2 of the key areas identified within the 2010 Women's Health Services Research Agenda have failed to show significant growth. These include primary care and prevention and complex chronic conditions/long-term care and aging (Table 15). Given the nature of the literature, we subdivided these articles to group studies on prevention/screening, those related to long-term care and aging, and those that addressed specific medical conditions or healthcare organization and delivery. We found that the number of studies related to prevention/screening actually dropped over time from 11 the first half of the review period to 7 the second half, and the single RCT on this topic was captured in the previous review.^338^ Most cancer-related screening articles described breast cancer only, and aside from a single study on “female-specific” cancer screening in general, there were no studies related to cervical cancer, which has a prescribed screening regimen that shifted throughout this review period, or ovarian and uterine cancers, which do not. As the female Veteran population begins to age, cancer-related screening research will become even more prescient. There was also only one study related to immunizations.

Table 15 Shortfalls and Limitations within the Literature

Research Priority areas | | Limitations/Gaps
Topics | Prevention and Screening | Decrease in publications over time Limited focus (primarily breast cancer)
Topics | Long-term Care and Aging | No increase in research Few studies pertinent to medical conditions of aging
Topics | Primary Care Complex Chronic Conditions | Few studies related to common chronic diseases or mental health issues seen in primary care No RCT/CCTs on medical topics
Study Design and Presentation | Experimental Studies | Very few RCT/CCTs
Study Design and Presentation | Comparison Groups | Many studies describe gender differences only
Study Design and Presentation | Funding | A substantial proportion of studies fail to identify a funding source

The number of studies related to long-term care and aging, a historically limited area of research,^447^ remained relatively flat throughout the 8 year review period, with 6 published in the first half and 7 the second half (though 4 of these were released in 2015, which may portend a coming increase). Only 3 studies addressed osteoporosis, 3 described postmenopausal hormone therapy, and none addressed arthritis or moderate to advanced dementia. Though there was one RCT related to mild cognitive impairment, it was a small, single-site study published in 2010 that has generated no additional secondary studies or larger trials to date. Nearly 70% of the studies we identified reported the age of female study participants (303/440 or 69%) and nearly all of the studies that included only women did so (180/187 or 96%). Nevertheless, collecting and describing this information does not seem to have translated into secondary or subgroup analyses by age thus far, which may be a first step in the development of knowledge specific to older women Veterans.

We elected not to separate medical topic studies using the categories of primary care and complex chronic conditions due to challenges mapping the literature within these headings. For example, we felt that diabetes research clearly applied to both categories, whereas other common medical conditions, such as cardiovascular disease, were not readily captured by either. Instead, we categorized articles by specific medical condition, and found that relatively little research has been devoted to physical conditions (as opposed to mental health), specifically chronic diseases, that affect women Veterans. For example, only a handful of studies addressed diabetes and none specifically targeted hypertension. Even research related to cardiovascular disease, the broadest group of medical condition studies (k = 11), was largely confined to comparisons between men and women. Chronic pain, an area of great need as well as intense scrutiny both within and outside VA at present, produced only 7 studies in 8 years, none of which were multi-site VA studies or evaluated subpopulations such as racial/ethnic minorities, homeless, or incarcerated Veterans. Complex conditions that impact women Veterans, such as spinal cord injury and amputees, were limited to a single large observational study each with a tiny proportion of women study subjects. There were no randomized trials and few qualitative studies related to medical conditions. In addition, we noted that the field of mental health research continues to grow, particularly with respect to specialty mental health treatments for PTSD and MST; there were nearly as many PTSD (k = 71) studies as all general medical studies (k = 78). However, mental health conditions most often encountered by primary care providers, including depression, anxiety, and postpartum depression, were largely absent from the literature.

### Shortfalls in Study Design and Presentation

The most obvious study design limitation of the literature base identified in this review is the very small number of experimental studies. We identified only 8 controlled interventional trials over the course of 8 years that related to women Veterans, and 2 of these had already been described in the previous review. Only half of the 8 RCTs were VA-funded and only 3 took place at multiple VA sites.

Another limitation noted in our review, was the proportion of studies that address women Veterans solely in comparison to male Veterans. Describing differences or disparities between female Veterans and the remainder of the largely male VA population has been a necessary initial step in establishing this field. Looking forward, however, we encourage further study of the broad range of patient demographic, health condition, and social determinant characteristics that exists within the population of women Veterans. For example, comparing racial or socioeconomic subgroups of women Veterans across or within health conditions may help identify or describe needs of particularly vulnerable populations. This approach parallels that endorsed by the NIH's Office of Research on Women's Health strategic plan for women's health research.^448^ Expanding the outcomes of interest beyond gender differences and disparities will further advance women Veterans' health research.

Finally, a notable finding in our review was the large proportion of studies (1 in 5) that did not report a source of funding. This was a particular problem for the growing categories of post-deployment health and homelessness. Reporting the source of funding and role of the funder is considered a quality standard for both experimental^449^ and observational^450^ research studies. Though it is possible that much of women Veterans' health research remains unfunded, only a small number of studies specifically identified an absence of funding. Far more studies simply did not address funding source within the text. This is an easily remedied shortfall that will strengthen the integrity of the research base while providing information for stakeholders reviewing current and potential sources of funding to expand women Veterans' health research.

## FUTURE DIRECTIONS

### Capturing Ongoing Research

One of the initial limitations we encountered in developing this literature map was the large quantity of published articles that included women Veterans but did not provide explicit outcome results for women Veterans (instead providing results only for the complete study population). In this situation, study results cannot be directly interpreted and applied by women Veterans' providers and researchers. In fact, we identified over 350 articles that included women Veteran study subjects but were excluded from this review because sex-specific results were not reported. This number approaches the final quantity of included studies in the review. The need for sex-specific reporting of scientific research results has been recognized by both the NIH^448^ and the Institute of Medicine.^451^ Multiple challenges of sex-specific reporting with respect to study design, statistical analysis, and results reporting exist.^452^ Research related to Veterans, which often utilizes the national VA administrative databases, may be more likely to have the statistical power to report subgroup analysis by sex or gender than non-VA health research. Additionally, VA, as a source of research funding, may have the ability to require the inclusion of women and specific results-reporting for women in research studies. Women Veterans' health stakeholders should champion efforts to capitalize on the large body of research in which women Veterans are already participating.

### Social and Cultural Transitions

Social and cultural shifts within both the US military and American society will also provide opportunities for expanded research related to women Veterans' health. Notable examples include experiences of LGBT Veterans following the end of the “Don't Ask Don't Tell” policy (2011) and the more recent move to allow openly transgender service members (2016). The expanding role of women in combat following the lifting of the Combat Exclusion Policy (2013) may have significant implications for research related to TBI, SCI, and amputees, all areas that are currently lacking for women Veterans. Increased combat exposure may also result in a higher burden of and shift in the etiology of PTSD among women Veterans. Finally, a transition in the national discussion of sexual assault, including the proliferation of “Affirmative Consent” policies on college campuses, may filter into future research and policy related to Military Sexual Trauma, which has unfortunately affected so many women Veterans.

### Veteran Engagement

VA is increasingly seeking to engage Veterans in research by including Veteran stakeholder perspectives in research processes such as development of study questions, selection of outcome measures, and interpretation of findings. None of our included studies described Veteran engagement as a component of their methods. Although several studies incorporated Veterans' perspectives (eg, qualitative input to improve an intervention), they all adhered to a traditional model in which the women were study subjects, rather than research stakeholders or partners.

## LIMITATIONS

There are several inherent limitations in a review of such a broad body of literature.

### Study Review and Data Abstraction

Given the large number of abstracts reviewed (2,276), we did not perform a dual review of all abstracts. However, our exclusion criteria were minimal and most abstracts were either excluded for very clear reasons (eg, our “VA” search criteria produced many studies related to “visual acuity” or “vertebral artery”) or else forwarded on for full-text review. Additionally, the 20% sample of abstracts that was dual-reviewed did not reveal systematic biases.

We were also limited in our ability to perform a systematic full-text dual review and data extraction by 2 investigators for each of 1,184 articles. However, we utilized a “second reviewer” system for a random sample of studies as well as any additional studies that the original reviewer had questions about, and a “group arbitration” system for studies about which 2 reviewers disagreed. To ensure consistency in definitions, a single additional reviewer was assigned to evaluate all included studies in categories that were inherently subjective (particularly “other” categories) and these were then double-reviewed by a second investigator. The principal investigator also performed additional checks while summarizing the findings by extracted categories. Though limitations remain due to the subjective and overlapping nature of many of the categories of data extracted, we are confident that our final database has been thoroughly reviewed and represents a best attempt to organize and evaluate this large body of literature.

### Applicability of Findings to the VA Population

We included studies of women Veterans both within and outside of the VA health system. Though generally relevant for VA women's health providers and researchers, some included studies may be more pertinent to the VA population than others.

## OPPORTUNITIES FOR EXPANDED REVIEWS

This broad evidence map identifies and describes 440 articles across 36 healthcare categories and 13 additional elements of study design and presentation. Advancing specific fields of research and the provision of quality healthcare to women Veterans will require additional in-depth reviews of study quality and bias, as well as a synthesis of outcomes, all of which were outside the scope of this review. This evidence map can be used to prioritize additional reviews and meta-analyses of specific determinants of or treatments for specific health conditions or populations.

For example, we identified (and searched the included studies of) several recent systematic reviews of women Veterans with PTSD,^453-455^ substance abuse,^456,457^ and mental health concerns in general.^458^ Within the field of women Veterans' mental health, however, additional reviews related to military sexual trauma, the delivery of mental healthcare, or integration/coordination with primary care could be considered.

In 2014, Bielawski and colleagues produced a special report updating the previous women Veterans' health systematic review specifically with respect to 5 chronic conditions.^459^ Future systematic reviews or meta-analyses could address issues of multimorbidity or primary care for racial/ethnic or sexual/gender minority women Veterans. Post-deployment health and reproductive health are both emerging areas of research for women Veterans that could benefit from focused systematic reviews to help direct future research. Finally, synthesizing the substantial research we identified into the delivery of care for women Veterans, with respect to access, rural health concerns, and organization of care will help inform future policies and care delivery decisions.

## CONCLUSIONS

We reviewed the recent published literature related to all topics in women Veterans' health. This large and varied body of research represents a growing evidence base that can be leveraged to improve the health of women Veterans. Though significant progress has been made toward achieving the ambitious research agenda set forth during the 2010 VA Women's Health Services Research Conference, we have identified several persistent knowledge gaps and research shortfalls. VA research and clinical stakeholders can use this evidence map to help direct the future of women Veterans health research.